# Abbreviations

AHRQ: Agency for Health Research and Quality
CER: Comparative Effectiveness Review
CHr: Hemoglobin content of reticulocytes
CKD: Chronic Kidney Disease
EPC: Evidence-based Practice Center
ESA: Erythropoiesis-stimulating agent
FRN: Future Research Needs
Hb: Hemoglobin
HD: Hemodialysis
IV: Intravenous
FRN: Future research needs
%HYPO: Percentage of hypochromic erythrocytes
PD: Peritoneal dialysis
PICOD: Population, Intervention, Comparator, Outcomes, and study Design
RBC: Red blood cell
RCT: Randomized controlled trial
RetHe: Reticulocyte hemoglobin equivalent
sTfR: Soluble transferrin receptor
TSAT: Transferrin saturation
ZPP: Zinc protoporphyrin