# References

1 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. Jan. Suppl 1. 2010;33:S62-9. [pmid: 20042775].
2 Cowie CC, Rust KF, Ford ES, et al. Full accounting of diabetes and pre-diabetes in the U.S. population in 1988–1994 and 2005–2006. Diabetes Care. Feb. 2009;32(2):287-94. [pmid: 19017771].
3 Engelgau MM, Geiss LS, Saaddine JB, et al. The evolving diabetes burden in the United States. Ann Intern Med. Jun. 1. 2004;140(11):945-50. [pmid: 15172919].
4 Centers for Disease Control and Prevention (CDC). Crude and age-adjusted incidence of diagnosed diabetes per 1000 population, United States, 1980–2007. Atlanta, GA. Centers for Disease Control and Prevention (CDC).
5 Nathan DM, Cleary PA, Backlund JY, et al. Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications (DCCT/EDIC) Study Research Group. Intensive diabetes treatment and cardiovascular disease in patients with type 1 diabetes. N Engl J Med. Dec. 22. 2005;353(25):2643-53. [pmid: 16371630].
6 Holman RR, Paul SK, Bethel MA, et al. 10-year follow-up of intensive glucose control in type 2 diabetes. N Engl J Med. Oct. 9. 2008;359(15):1577-89. [pmid: 18784090].
7 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. the diabetes control and complications trial research group. N Engl J Med. Sep. 30. 1993;329(14):977-86. [pmid: 8366922].
8 Kitzmiller JL, Block JM, Brown FM, et al. Managing preexisting diabetes for pregnancy: Summary of evidence and consensus recommendations for care. Diabetes Care. May. 2008;31(5):1060-79. [pmid: 18445730].
9 Golden SH, Brown T, Yeh HC, et al. Methods for Insulin Delivery and Glucose Monitoring: Comparative Effectiveness. Comparative Effectiveness Review No. 57. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.). AHRQ Publication No. 12-EHC036-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
10 CDC’s Diabetes Program - Data & Trends - Prevalence of Diabetes [Internet]. c2011. [cited 2011 July] www.cdc.gov/diabetes/statistics/prev/national/figraceethsex.htm.
11 Workgroup on Hypoglycemia, American Diabetes Association. Defining and reporting hypoglycemia in diabetes: A report from the american diabetes association workgroup on hypoglycemia. Diabetes Care. May. 2005;28(5):1245-9. [pmid: 15855602].
12 Pickup JC, Freeman SC, Sutton AJ. Glycaemic control in type 1 diabetes during real time continuous glucose monitoring compared with self monitoring of blood glucose: Meta-analysis of randomised controlled trials using individual patient data. BMJ. Jul. 7. 2011;343:d3805. [pmid: 21737469].
13 Beck RW, Hirsch IB, Laffel L, et al. Juvenile Diabetes Research Foundation Continuous Glucose Monitoring Study Group. The effect of continuous glucose monitoring in well-controlled type 1 diabetes. Diabetes Care. Aug. 2009;32(8):1378-83. [pmid: 19429875].
14 Genuth S, Eastman R, Kahn R, et al. American Diabetes Association. Implications of the United Kingdom prospective diabetes study. Diabetes Care. Jan. Suppl 1. 2003;26:S28-32. [pmid: 12502617].