# Addendum

This report was posted for public comment on the AHRQ Effective Health Care Web site from March 1, 2013, to March 28, 2013. In response to the comments received, the authors added the following discussion points:

1. We acknowledge the importance of studying minority subgroups who may experience disproportionately higher rates of complications related to diabetes. The original systematic review by Golden et al. found most previous studies did not report the racial and ethnic composition of the study samples. For those studies that did, most participants were white. This is probably because type 1 diabetes mellitus is more prevalent in whites than in minority populations. This was cited as an evidence gap in the original report, and we agree that recruitment of minority patients in research studies is important.
2. While our report identified real-time-continuous glucose monitoring (rt-CGM) as “superior” to self-monitoring of blood glucose (SMBG) in lowering HbA1c, it is important to note, consistent with the original systematic review, that all of the rt-CGM devices add to, but don’t replace, regular blood sugar checks with a glucometer.
3. While data on long-term microvascular or macrovascular complications would be informative, it would require a large RCT several years in duration. Also this type of RCT may not be feasible, particularly because persons may switch therapies over time. Additional patient sources, such as a registry or clinical network (e.g. T1D Exchange) may be required to identify potential participants. Moreover, we acknowledge that future studies should better study quality of life as an outcome. We did not include other outcomes, such as glucose variability and hypoglycemia awareness, as specific research needs because they were not within the scope of the original review by Golden et al., and thus cannot ascertain what research may have already addressed these questions, although we acknowledge their importance.
4. We recognize additional research may be required to better study the potential interactions between adiposity, physical activity and clinical outcomes such as HbA1c, QOL, functional and fitness measurements, and microvascular or macrovascular disease progression. We did not include this as specific research need because it was not within the scope of the original review by Golden et al., and thus cannot ascertain what research may have already addressed this question, although we acknowledge its importance.
5. We acknowledge that our stakeholder group may not be representative of all those who have a stake in research on insulin delivery and glucose monitoring. A different type of study (e.g., a survey) might be needed to further explore the views of stakeholders about the research priorities we identified. However, the value of the Delphi method is to obtain agreement in a small group without having any one person dominate the process. The method is efficient without geographic constraints, and allows all group members to have an equal voice. Although the optimal number of stakeholders in a Delphi study never reaches a consensus in the literature, a small number may be sufficient when the stakeholders have a similar level of familiarity with the topic. Following the constraints of our project timeline, we aimed to recruit a small panel of 5–9 stakeholders. We invited 14 experts in the field of insulin delivery and glucose management to serve as expert stakeholders until we had at least 5 stakeholders who were able to participate in the process. The final five-member stakeholder panel included one academic physician in the field of pediatric endocrinology, three physicians in the field of adult endocrinology, and one patient with type 1 diabetes mellitus for more than 50 years. All endocrinologist stakeholders are experienced clinicians, who handled complicated diabetic patients and had experience in managing patients with all modalities included in the report.