# Acknowledgments

The Johns Hopkins University Evidence-based Practice Center thank the other authors of the 2012 Comparative Effectiveness Review on Insulin Delivery and Glucose Monitoring Methods, and the stakeholder representatives that provided input on this report (each listed below).