# Conclusion

For type 1 diabetes, three expert Stakeholders ranked adolescents as the highest priority among patients with type 1 diabetes for future research, and three Stakeholders ranked artificial pancreas as the highest priority for future research. For glucose monitoring methods, all stakeholders prioritized rt-CGM for anyone with type 1 diabetes. For younger populations (children and adolescents) adherence was ranked highest by many Stakeholders. For adults and elderly, the majority ranked severe hypoglycemia as high priority. Among insulin-requiring patients with type 2 diabetes, three stakeholders ranked adults as the highest priority. For all patients with insulin-requiring type 2 diabetes, three stakeholders ranked sensor-augmented insulin pump as the highest research need for insulin delivery. Likewise, for glucose monitoring methods, three stakeholders prioritized rt-CGM for patients with insulin-requiring type 2 diabetes. For outcomes, majority of the stakeholders ranked HbA1c as the highest priority.