# Search Strategies for Ongoing Studies

Resource URL | Search Parameters | Search Terms/Strategy
ClinicalTrials.gov clinicaltrials.gov/ | Advanced search, Conditions field used | Insulin pump OR continuous subcutaneous insulin infusion therapy OR CSII
EU Clinical Trials Register www.clinicaltrialsregister.eu/ | Not applicable | Insulin pump OR continuous subcutaneous insulin infusion therapy OR CSII
NIH Reporter projectreporter.nih.gov/reporter.cfm | Projects field searched | Insulin pump OR continuous subcutaneous insulin infusion therapy OR CSII
Canadian Institutes of Health Research www.cihr-irsc.gc.ca/ | Funding Decisions Data field searched | Insulin pump OR continuous subcutaneous insulin infusion therapy OR CSII
World Health Organization International Clinical Trials Registry Platform Search Portal apps.who.int/trialsearch/ | Searched Condition field, Recruitment status = ALL | Insulin pump OR continuous subcutaneous insulin infusion therapy OR CSII

Abbreviation: CSII = continuous subcutaneous insulin infusion.