# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
CGM: Continuous glucose monitoring
CSII: Continuous subcutaneous insulin infusion
EPC: Evidence-based Practice Center
HbA1c: Hemoglobin A1c
KQ: Key Question
MDI: Multiple daily injections
RCT: Randomized controlled trial
rt-CGM: Real-time continuous glucose monitoring
SMBG: Self-monitoring of blood glucose
U.S.: United States