# Results

Identified gaps for childhood obesity prevention were listed by population (Table 3), intervention (Table 4) and setting (Table 5). Results from the stakeholder prioritization are presented as below.

Table 3 Round 1 stakeholder votes for highest priority population of children for future research

Age Groups | Votes (N=6)
Toddler (2–5) | 2
Childhood (6–12) | 1
Adolescence (13–18) | 0
All children (2–18) | 3^*^
Socioeconomic Groups | Votes (N=6)
High income | 0
Middle income | 0
Low income | 3^*^
All income groups | 3^*^
Racial/Ethnic Groups | Round 1 (N=6)
Asian/Pacific Islander | 0
Black | 0
Hispanic | 1
Native American | 0
White | 0
All race/ethnicity groups | 5^*^

* Indicates prioritized research need.

Table 4 Round 1 stakeholder votes for interventions for future research

Targets | Highest Priority | Lowest Priority
Targets | Votes (N=6) | Votes (N=6)
Diet | 1 | 0
Physical Activity\Sedentary Behavior | 0 | 5
Combination of Interventions | 4^*^ | 1
Other | 1 | None stated

* Indicates prioritized research need.

Table 5 Round 1 stakeholder votes for settings for future research

Settings | Highest Priority | Lowest Priority
Settings | Votes (N=6) | Votes (N=6)
School | 2 | 4
Home | 5^*^ | 0
Primary Care | 1 | 0
Child Care | 2 | 1
Community or Environment | 3^*^ | 1
Multiple Setting | 5^*^ | Not asked

* Indicates prioritized research need.

## Populations of High Interest

During round 1, the majority of the six stakeholders suggested that future studies should enroll children from all age groups (2–18 years), from all income strata or selectively enroll children from low income families. They felt that children of all races or ethnicities would be important to study (see Table 3).

## Intervention Targets

During round 1, four of six stakeholders regarded a combination of interventions as the priority for future rather than interventions focusing solely on diet or physical activity/sedentary behavior (see Table 4).

## Settings of Intervention

During round 1, multiple setting or home was voted as highest priority by five of six stakeholders (see Table 5). The stakeholders did not favor additional studies in schools.

Upon selection of combinations of specific populations, and individual targets, interventions, and settings by stakeholders in round 2, other patterns emerged. The stakeholders consistently favored prioritizing school-aged children (6 to 12 year-olds); they also favored low income groups for further study and Hispanic children.

When the stakeholders were asked to specify the target of intervention during round 2, they favored future research about the impact of caloric restriction as opposed to dietary composition. Physical activity interventions were not a favored strategy for future research. Similarly, when asked to specify the highest priority settings of interest, the stakeholders selected the home setting as the priority setting for future research, followed by the community setting. The results from round 2 allowed us to generate the research questions that were presented to the stakeholders in round 3. They are shown below along with the mean Likert rating from the stakeholders, which reflect the value placed on these questions to address research needs about childhood obesity prevention (see Table 6).

Table 6 Stakeholder rating of the value in addressing each research question

Research Question | Mean Rating^*^
Among LOW-INCOME TODDLERS, what is the comparative effectiveness of a HOME-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | 3.8
Among LOW-INCOME YOUNG CHILDREN, what is the comparative effectiveness of a HOME-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | 3.8
Among LOW-INCOME YOUNG CHILDREN, what is the comparative effectiveness of a HOME + COMMUNITY-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | 3.8
Among LOW-INCOME TODDLERS, what is the comparative effectiveness of a HOME + COMMUNITY-based intervention versus NO INTERVENTION targeting caloric intake to prevent weight gain? | 3.6
Among LOW-INCOME HISPANIC TODDLERS, what is the comparative effectiveness of a HOME-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | 3.6
Among LOW-INCOME HISPANIC TODDLERS, what is the comparative effectiveness of a HOME + COMMUNITY-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | 3.4
Among LOW-INCOME HISPANIC YOUNG CHILDREN, what is the comparative effectiveness of a HOME + COMMUNITY-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | 3.4
Among LOW-INCOME YOUNG CHILDREN, what is the comparative effectiveness of a HOME-based versus HOME + COMMUNITY-based intervention targeting caloric intake to prevent weight gain? | 3.2
Among LOW-INCOME HISPANIC YOUNG CHILDREN, what is the comparative effectiveness of a HOME-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | 3.2
Among LOW-INCOME HISPANIC YOUNG CHILDREN, what is the comparative effectiveness of a HOME-based versus HOME + COMMUNITY-based intervention targeting caloric intake to prevent weight gain? | 3.0
Among LOW-INCOME TODDLERS, what is the comparative effectiveness of a HOME-based versus HOME + COMMUNITY-based intervention targeting caloric intake to prevent weight gain? | 2.8
Among LOW-INCOME HISPANIC TODDLERS, what is the comparative effectiveness of a HOME-based versus HOME + COMMUNITY-based intervention targeting caloric intake to prevent weight gain? | 2.4

* 1 is the lowest value and 5 is the highest value.

## Methodological Needs in the Body of Evidence

When the stakeholders were presented with methodological gaps which the team identified as prevalent in this body of literature, they responded by stating their three highest priority methodological issues that should be address in future research. They are ordered by the number of votes by the stakeholders (with each contributing three votes; see Table 7).

Table 7 Stakeholder rating of high-priority methodological gaps which should be addressed in future research studies of childhood obesity prevention (from round 1)

Methodological Gaps | Votes
Improved methods for evaluation of community-based interventions | 4
Description of barriers and facilitators to implementing programs | 3
More rigorous analytic approaches (i.e., to better analyze the repeated measures collected during the follow-up) | 3
Consideration of scalability of the intervention at the time of study design | 2
Greater fidelity to study intervention | 2
Use of standardized definitions for overweight and obesity | 2
Assessment and reporting on adverse effects of the intervention | 0
Masking of outcome assessor to study group assignment | 0

## Research Questions and Research Design Considerations

The optimal research design and other research considerations are presented in Table 8.

Table 8 High priority research questions and research design considerations for each question

Research Question | Research Design Considerations
Among LOW-INCOME TODDLERS, what is the comparative effectiveness of a HOME-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | Best answered with RCT, recruitment might be at physicians’ offices or through public assistance offices, may require home visits to assure fidelity to intervention, scalability will depend on intensity of intervention
Among LOW-INCOME YOUNG CHILDREN, what is the comparative effectiveness of a HOME-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | Best answered with RCT, recruitment might be through physician offices or schools, may require home visits to assure fidelity to intervention, scalability will depend on intensity of intervention
Among LOW-INCOME YOUNG CHILDREN, what is the comparative effectiveness of a HOME + COMMUNITY-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | Best answered with RCT, recruitment and implementation might be at churches or community centers, may benefit from a community-based participatory research framework, scalability will depend on intensity of intervention, randomization might be at level of community
Among LOW-INCOME TODDLERS, what is the comparative effectiveness of a HOME + COMMUNITY-based intervention versus NO INTERVENTION targeting caloric intake to prevent weight gain? | Best answered with RCT, recruitment and implementation might be at churches or community centers, may benefit from a community-based participatory research framework, scalability will depend on intensity of intervention, randomization might be at level of community
Among LOW-INCOME HISPANIC TODDLERS, what is the comparative effectiveness of a HOME-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | Best answered with RCT, recruitment might be at physicians’ offices or through public assistance offices, may require home visits to assure fidelity to intervention, scalability will depend on intensity of intervention, will require a culturally-appropriate intervention and availability of Spanish language materials if needed
Among LOW-INCOME HISPANIC TODDLERS, what is the comparative effectiveness of a HOME + COMMUNITY-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | Best answered with RCT, recruitment and implementation might be at churches or community centers, may benefit from a community-based participatory research framework, scalability will depend on intensity of intervention, randomization might be at level of community, will require a culturally-appropriate intervention and availability of Spanish language materials if needed
Among LOW-INCOME HISPANIC YOUNG CHILDREN, what is the comparative effectiveness of a HOME + COMMUNITY-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | Best answered with RCT, recruitment and implementation might be at churches or community centers, may benefit from a community-based participatory research framework, scalability will depend on intensity of intervention, randomization might be at level of community, will require a culturally-appropriate intervention and availability of Spanish language materials if needed
Among LOW-INCOME YOUNG CHILDREN, what is the comparative effectiveness of a HOME-based versus HOME + COMMUNITY-based intervention targeting caloric intake to prevent weight gain? | Best answered with RCT, recruitment and implementation might be at churches or community centers, may benefit from a community-based participatory research framework, scalability will depend on intensity of intervention, randomization might be at level of community
Among LOW-INCOME HISPANIC YOUNG CHILDREN, what is the comparative effectiveness of a HOME-based intervention targeting caloric intake versus NO INTERVENTION to prevent weight gain? | Best answered with RCT, recruitment might be at physicians’ offices or schools, may require home visits to assure fidelity to intervention, scalability will depend on intensity of intervention, randomization might be at level of community, will require a culturally-appropriate intervention and availability of Spanish language materials if needed
Among LOW-INCOME HISPANIC YOUNG CHILDREN, what is the comparative effectiveness of a HOME-based versus HOME + COMMUNITY-based intervention targeting caloric intake to prevent weight gain? | Best answered with RCT, recruitment and implementation might be at churches or community centers, may benefit from a community-based participatory research framework, scalability will depend on intensity of intervention, randomization might be at level of community, randomization might be at level of community, will require a culturally-appropriate intervention and availability of Spanish language materials if needed
Among LOW-INCOME TODDLERS, what is the comparative effectiveness of a HOME-based versus HOME + COMMUNITY-based intervention targeting caloric intake to prevent weight gain? | Best answered with RCT, recruitment may be from public services offices or physicians’ offices and implementation might be at churches or community centers, may benefit from a community-based participatory research framework, scalability will depend on intensity of intervention, randomization might be at level of community, randomization might be at level of community, will require a culturally-appropriate intervention and availability of Spanish language materials if needed
Among LOW-INCOME HISPANIC TODDLERS, what is the comparative effectiveness of a HOME-based versus HOME + COMMUNITY-based intervention targeting caloric intake to prevent weight gain? | Best answered with RCT, recruitment may be from public services offices or physicians’ offices and implementation might be at churches or community centers, may benefit from a community-based participatory research framework, scalability will depend on intensity of intervention, randomization might be at level of community, randomization might be at level of community, will require a culturally-appropriate intervention and availability of Spanish language materials if needed

Abbreviation: RCT = randomized controlled trial

All of the above designs should carefully track participants and aim for high participant retention; these studies are still at the point of requiring demonstration of the efficacy of the intervention. At the point of expanding the intervention for broader implementation, questions about the effectiveness can be addressed. These may include questions about the feasibility of implementation in different communities, the feasibility of local clinicians or educators assuming the roles of the study staff, and the acceptance of the intervention by the targeted population. The community-based interventions should aim to follow the same children across time rather than doing serial cross-sectional studies which are a weaker design. All studies should report BMI-z score rather than just BMI. Studies should pre-specify their analytic plan regarding multiple measures over time.

## Research in Progress

Upon review of five clinical study repositories (Appendix B), we found 12 potentially relevant ongoing studies to address the gaps in the literature regarding obesity prevention in children (Appendix C). Six studies have a combination of targets including behavior, nutrition, and physical activity, four studies target behavioral modifications, one study targets changes in nutrition only, and one study targets changes physical activity only.