# References

1 Centers for Disease Control (CDC). Childhood overweight and obesity. Centers for Disease Control (CDC). Updated March 31, 2010. www.cdc.gov/obesity/childhood/index.html.
2 Wang Y, Lobstein T. Worldwide trends in childhood overweight and obesity. Int J Pediatr Obes. 2006;1(1):11-25. [pmid: 17902211].
3 Ogden CL, Carroll MD, Curtin LR, et al. Prevalence of high body mass index in US children and adolescents, 2007–2008. JAMA. Jan. 20. 2010;303(3):242-9. [pmid: 20071470].
4 Olson CM, Demment MM, Carling SJ, et al. Associations between mothers’ and their children’s weights at 4 years of age. Child Obes. Aug. 1. 2010;6(4):201-7. [pmid: 21743836].
5 Birch LL, Anzman-Frasca S. Promoting children’s healthy eating in obesogenic environments: Lessons learned from the rat. Physiol Behav. Sep. 26. 2011;104(4):641-5. [pmid: 21620880].
6 Wang Y, Beydoun MA. The obesity epidemic in the United States—gender, age, socioeconomic, racial/ethnic, and geographic characteristics: A systematic review and meta-regression analysis. Epidemiol Rev. 2007;29:6-28. [pmid: 17510091].
7 Wang Y, Wu Y, Wilson RF, et al. Childhood Obesity Prevention Programs: A Comparative Effectiveness Review and Meta-Analysis. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.). AHRQ Publication No. 13-EHC081-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
8 Carey TS, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. (Prepared by RTI-UNC Evidence-based Practice Center under Contrat No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/ehc/products/348/1001/MFRN-8_Framework-for-Considering-Study-Designs_DraftReport_20120308.pdf. [pmid: 22624168].
9 Bennett WL, Nicholson WK, Saldanha IJ, et al. Future Research Needs for the Management of Gestational Diabetes. Future Research Needs Paper No. 7. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 11-EHC005-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2010. www.effectivehealthcare.ahrq.gov/reports/final.cfm. [pmid: 21433329].