# Methods

The protocol for developing the evidence gaps into a prioritized list of research needs and feasible researchable questions involved the following steps: identification of evidence gaps; engagement of stakeholders; prioritization of PICOTS elements as Future Research Needs through a modified Delphi process; development of research questions and study design considerations by the research team; and prioritization of research questions through a modified Delphi process.

## Identification of Evidence Gaps

To identify evidence gaps, our research team abstracted evidence gaps from the 2012 draft evidence report Childhood Obesity Prevention Programs: A Comparative Effectiveness Review and Meta-Analysis. 7 The investigators identified evidence gaps based on the strength of evidence, applicability, and limitations of the review. All evidence statements with low or insufficient strength were considered evidence gaps.

## Engagement of Stakeholders

We invited previous stakeholders from the Comparative Effectiveness Review, as well as new participants. We recruited a variety of stakeholder perspectives with potential interest in childhood obesity prevention such as parents, researchers, and representatives from government and public agencies. Stakeholders were recruited via email, letter and phone invitations. All participating stakeholders provided copies of their curriculum vitae and disclosure statements to ensure that all potential conflicts of interest were disclosed. The list of stakeholders and their disclosure statements were approved by AHRQ.

Stakeholders received a copy of the Executive Summary from the draft 2012 evidence report Childhood Obesity Prevention Programs: A Comparative Effectiveness Review and Meta-Analysis and were asked to read this in preparation. The stakeholders participated in a three-round prioritization process by responding to our questions via a Web-based assessment tool (SurveyMonkey, Palo Alto, CA; Appendix A). The assessments included multiple choice and dropdown menus. We allowed the respondents to clarify their responses with written comments but these were not considered integral to the process. Stakeholders were compensated for their time.

## Criteria for Prioritization

The stakeholders participated in a three-round modified Delphi process during which they prioritized the evidence gaps. Stakeholders were asked to base their responses upon their review of the Executive Summary of the draft evidence report and the evidence gaps described in that document. We did not otherwise impose any criteria for how they should prioritize the elements Rounds 1 and 2. During round 3 they were asked to prioritize based on the “potential impact of the results of the question.” We defined consensus as a majority of respondents identifying an element as being among the highest priority or among the lowest priority.

Delphi Round 1: Prioritization of Populations, Interventions, Intermediate Outcomes, and Settings. Stakeholders were asked to rate the highest priority populations, and the highest and lowest priority interventions and settings for future research in childhood obesity prevention. Populations were defined on the basis of age (all ages, toddlers, young children, adolescents), race/ethnicity (all races/ethnicities, Black, Hispanic, Native American, white), and socioeconomic status (all income levels, low, middle, high). Interventions were defined as dietary, physical activity, or both. Intermediate outcomes were defined as nutrition knowledge, food purchasing behaviors, or dietary intake. Settings were defined as school, home, primary care, child care, community/environment, or multiple settings. We assumed that weight is the primary outcome and did query the stakeholders about other primary or clinical outcomes. Due to variation in the number of evidence gaps across categories, the number of items that the stakeholders could identify as highest priority varied depending on the category: one highest for each of the demographic categories, one highest for intervention, and three highest for setting. For each category, they were also asked to specify the one lowest priority.

In this round, we also asked the stakeholders to comment on methodological limitations in the literature which we reviewed for the systematic review. We asked the stakeholders to consider aspects of study design and reporting that should be included in future research.

They were asked to select the three highest priority methodological issues that should be addressed in future research, from those below:

- Use of standardized definitions for overweight and obesity
- Use of more rigorous analytic approaches
- Masking of outcome assessor to study group assignment
- Improved methods for evaluation of community-based interventions
- Greater fidelity to study intervention
- Description of barriers and facilitators
- Consideration scalability of the intervention at the time of study design
- Assessment and reporting on adverse effects of the intervention

Delphi Round 2: Rating of Combinations of Populations, Interventions, and Settings. Based on the results of the first round, a second assessment was prepared. Evidence gaps for age, race/ethnicity, socioeconomic status, and intervention that achieved consensus as a high priority by a simple majority were included as sub-questions for refinement in this round of assessment. Settings that achieved consensus as a high priority for future research were included in round 2 in the form they were presented in round 1. The settings that achieved consensus as a low priority were excluded from subsequent rounds. Because combination interventions achieved the overwhelming support of the stakeholders in round 1, physical activity was advanced to the second round as it could not be reliably excluded. In this round, the stakeholders were asked to select combinations of populations, settings, and interventions (see Table 2). For each combination, stakeholders were allowed to select one age group, one race/ethnicity group, one socioeconomic status group, one setting, and one intervention.

Table 2 Options for Delphi Round 2

Age | Race/Ethnicity | Socioeconomic Status | Setting | Target
Young | Black | Low income | Clinic | Caloric intake
Toddler | Hispanic | Middle income | Community | Physical activity
Adolescent | Native American | | Home | Diet composition
| White | | | Sleep

The options were presented to the stakeholders so that they had to select one from each category (age, race/ethnicity, socioeconomic status, setting, and target), using dropdown menus, and identify the combination as a priority combination. The stakeholders were asked to select five combinations as priorities. An example may be: a home-based study of caloric intake modification for low-income Black toddlers.

Delphi Round 3: Rating of Research Questions. In round 3, we presented the stakeholders with a list of research questions that our team generated based on their feedback in Rounds 1 and 2. The team phrased the questions as high-priority interventions compared with no intervention, (rather than compared with another active intervention). The questions about settings were phrased as high-priority settings compared with other high-priority settings. The stakeholders rated each question on a Likert scale from 1 to 5 to indicate the value of addressing each question in future research. They were asked to consider to what extent having an answer to the question would improve obesity prevention efforts. Their responses were compiled and reported as a mean score for each question.

## Research Design Considerations

Our team took the list of prioritized questions and considered the aspects of study design8 and conduct that would best answer the research question. These were not discussed with the stakeholders as they were not uniformly experts in research methodology.

## Research in Progress

Clinical research repositories and research-related sites including ClinicalTrials.gov, NIH Reporter, the Canadian Institutes of Health Research, the World Health Organization International Clinical Trials Registry Platform Search Portal, and the European Union Clinical Trials Register were searched to identify ongoing or recently completed studies related to childhood obesity prevention. Appendix B details the search strategies used for each repository.