# Addendum

This report was posted for public comment from June 10, 2013 to July 8, 2013 on the Effective Health Care website. We received one set of comments from the American Therapy Association (APTA). The comments were related to gaps outside the scope of the original systematic review including the study of children with special healthcare needs; the limited number and perspectives of the stakeholder group; and the impact of these stakeholder perspectives on the final list of highest priority research needs. While we acknowledge the many research needs in this area, the scope of this report was constrained by that of the original systematic review. These comments were considered, and no changes were made in this report.