# Acknowledgments

The Johns Hopkins University Evidence-based Practice Center thanks the other authors of the 2012 draft evidence report on “Childhood Obesity Prevention Programs: A Comparative Effectiveness Review and Meta-Analysis,” and stakeholders external to Johns Hopkins University (each listed below).

## Contributors

- Benjamin Caballero, M.D., Ph.D.
  Johns Hopkins Bloomberg School of Public Health
  Baltimore, MD
- William Dietz, M.D.
  Centers for Disease Control and Prevention
  Atlanta, GA
- Stacy Passaro, P.E.
  Parent Stakeholder
  Baltimore, MD
- Nancy Sherwood, Ph.D.
  Health Partners Research Foundation
  Minneapolis, MN
- Mary Story, R.D., Ph.D.
  University of Minnesota
  Minneapolis, MN
- Joanne Spahn, R.D.
  Food and Drug Administration
  St. Louis, MO