# Conclusion

Using the 2012 draft evidence report “Childhood Obesity Prevention Programs: A Comparative Effectiveness Review and Meta-Analysis,” we identified and prioritized Future Research Needs. We identified 12 research questions considered to be of potential health impact by a multidisciplinary group of stakeholders. These questions focus on high-priority populations, interventions, comparisons, and settings as identified by our stakeholders. During the systematic review process, we identified methodological issues in the literature; our stakeholders agreed that improving these methods will benefit studies to come. This report may inform and support researchers to develop studies to evaluate the Key Questions identified, as well as enable funding agencies to dedicate their resources to areas most likely to make a health impact.