# Search Strategies for Potentially Relevant Ongoing Studies

Resource URL | Search Parameters | Search Terms/Strategy
ClinicalTrials.gov http://clinicaltrials.gov/ | Advanced search, Conditions field used | Prevent child obesity OR Prevent child overweight OR Prevent child weight gain Open Studies \| Exclude Unknown
EU Clinical Trials Register https://www.clinicaltrialsregister.eu/ | Not applicable | Prevent child obesity OR Prevent child overweight OR Prevent child weight gain
NIH Reporter http://projectreporter.nih.gov/reporter.cfm | Projects field searched | Prevent child obesity OR Prevent child overweight OR Prevent child weight gain
Canadian Institutes of Health Research http://www.cihr-irsc.gc.ca/ | Funding Decisions Data field searched | Prevent child obesity OR Prevent child overweight OR Prevent child weight gain
World Health Organization International Clinical Trials Registry Platform Search Portal http://apps.who.int/trialsearch/ | Searched Condition field, Recruitment status = ALL | Prevent child obesity OR Prevent child overweight OR Prevent child weight gain