# Data Collection Tool Sent to Stakeholders

Appendix A consists of three data collection tools sent to stakeholders. The stakeholders participated in a three-round prioritization process by responding to questions via a Web-based assessment tool, SurveyMonkey. The assessments included multiple choice and dropdown menus. Respondents were allowed to clarify their responses with written comments but these were not considered integral to the process. Round 1 consisted of 20 questions. Stakeholders were asked to rate the highest priority populations, and the highest and lowest priority interventions and settings for future research in childhood obesity prevention. Populations were defined on the basis of age (all ages, toddlers, young children, adolescents), race/ethnicity (all races/ethnicities, Black, Hispanic, Native American, white), and socioeconomic status (all income levels, low, middle, high). Interventions were defined as dietary, physical activity, or both. Intermediate outcomes were defined as nutrition knowledge, food purchasing behaviors, or dietary intake. Settings were defined as school, home, primary care, child care, community/environment, or multiple settings. In this round, stakeholders also were asked to comment on methodological limitations in the literature reviewed for the systematic review. Stakeholders were asked to consider aspects of study design and reporting that should be included in future research. They were asked to select the three highest priority methodological issues that should be addressed in future research, from a list of eight. Round 2 consisted of 10 questions. Based on the results of the first round, a second assessment was prepared. Evidence gaps for age, race/ethnicity, socioeconomic status, and intervention that achieved consensus as a high priority by a simple majority were included as sub-questions for refinement in this round of assessment. Settings that achieved consensus as a high priority for future research were included in round 2 in the form they were presented in round 1. The settings that achieved consensus as a low priority were excluded from subsequent rounds. Because combination interventions achieved the overwhelming support of the stakeholders in round 1, physical activity was advanced to the second round as it could not be reliably excluded. In this round, the stakeholders were asked to select combinations of populations, settings, and interventions. For each combination, stakeholders were allowed to select one age group, one race/ethnicity group, one socioeconomic status group, one setting, and one intervention. In round 3, stakeholders were given a list of research questions generated based on their feedback in rounds 1 and 2. The team phrased the questions as high-priority interventions compared with no intervention, (rather than compared with another active intervention). The questions about settings were phrased as high-priority settings compared with other high-priority settings. The stakeholders rated each question on a Likert scale from 1 to 5 to indicate the value of addressing each question in future research. They were asked to consider to what extent having an answer to the question would improve obesity prevention efforts. Their responses were compiled and reported as a mean score for each question.