# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BMI: Body mass index
EPC: Evidence-based Practice Center
RCT: Randomized controlled trial
U.S.: United States