# Results

## Recruitment and Participation

Nine of 21 invited stakeholders participated in the project. Out of the stakeholders we contacted, the Webinars and a phone interview included two of the six clinicians/researchers (33 percent); one of the five research funders (20 percent); three of the five policymakers (60 percent); two of the three patient advocates (67 percent); and one of the two representing social work/social services (50 percent) (See Table 1).

Table 1 Stakeholders who agreed to participate

Stakeholder Perspective (Assigned by Project Team) | Total Invited | Agreed | Participation Rate | Invited Organizations and Individuals
Clinical/Research | 6 | 2 | 33% | New Courtland Center for Transitions and Health, University of Pennsylvania; Indiana University; Department of Geriatric Medicine University of Oklahoma; NYU Langone Medical Center; Johns Hopkins Bloomberg School of Public Health; Frances Payne Bolton School of Nursing, Case Western Reserve University
Funder | 5 | 1 | 20% | Veterans Affairs; Center for Delivery, Organization and Markets, Agency for Health Research and Quality; National Institute on Aging; National Institute of Nursing Research; Centers for Medicare & Medicaid Services
Health Policy | 5 | 3 | 60% | Office of Health Insurance Programs New York State Department of Health; Oregon Health & Science University; Mathematica Policy Research
Social Work/Social Services | 2 | 1 | 50% | The John A. Hartford Foundation; New York Academy of Medicine, Social Work Leadership Institute
Patient Advocate | 3 | 2 | 67% | National Council on Aging; AARP; California Health Care Foundation
Total | 21 | 9 | 43%

AARP = American Association of Retired Persons; NYU = New York University

Of the nine stakeholders, three participated in the first Webinar and five participated in the second Webinar held about a week later. Stakeholders who participated in the first Webinar included one research funder, one clinician/researcher, and one health policymaker. The second Webinar included one clinician/researcher, one patient advocate, one stakeholder from social work/social services and two health policymakers. One stakeholder, a patient advocate, was interviewed separately due to scheduling conflicts. The second Webinar was also used as an opportunity for mentoring as two junior colleagues of a stakeholder attended.

After the completion of both Webinars and the phone conference, stakeholders were asked to respond first to a followup email and then complete an online questionnaire. Stakeholders often have numerous roles and bring several perspectives to a task based on prior as well as current experience, so we asked stakeholders to self report their primary perspective. Their self-reported perspectives as well as the perspective assigned by the research team at recruitment are reported in Table 2. Four of the nine self-identified perspectives matched up with that assigned by the research team. One stakeholder was invited as a policymaker but self-identified as a researcher; the remaining four opted for the “other” category and provided a category not specifically defined in the recruitment process.

Table 2 Perspectives of participating stakeholders

Respondent | Team Perspective Assigned | Self-Reported Perspective
1 | Clinical/Research | Researcher
2 | Funder | Funder
3 | Health Policy | Policymaker
4 | Health Policy | Other: Leader interested in system design
5 | Clinical/Research | Researcher
6 | Health Policy | Researcher
7 | Patient Advocate | Other: Multiple roles
8 | Social Work/Social Services | Other: Convener of national care coordination coalition
9 | Patient Advocate | Other: Organizational Innovation, Capacity and Quality

## Identification of Research Gaps

An initial list of potential topics for future research was compiled by project staff and then was sent to the stakeholders for comments, additions, and corrections. The revised list of 61 topics was finalized and used for the remainder of the rating and prioritization process. These items are listed below, organized according to PICOTS with the addition of an “other” category for overarching topics that did not fit into a PICOTS category.

### Population

Studies are needed to:

- Describe the characteristics of patients in CM programs that result in positive outcomes (benefits for patients or positive changes in utilization).
- Assess the use of risk assessment tools for choosing patients most likely to benefit from CM.
- Examine CM for patients with multiple comorbidities and issues (i.e., studies that do not exclude patients based on severity, diagnosis, or other aspects of need).
- Examine whether the known risk factors for rehospitalization (e.g., functional status, social support, number of past hospitalizations) would be useful in targeting CM.
- Incorporate large sample sizes (more power), e.g., large observational cohort studies, large trials and/or registries.
- Determine the impact of patient literacy (or the case manager's ability to address patient literacy) on effectiveness of CM.
- Assess the impact of patient activation (a specific measure that includes confidence, engagement, skills and knowledge) on the effectiveness of CM.
- Compare characteristics of patients who choose to participate with those who choose not to participate in CM.
- Compare CM programs that automatically enroll patients with programs where patients have to choose to enroll (i.e., opt-in vs. opt-out programs).
- Describe longitudinal evaluation of the impact of CM, particularly for those with chronic illnesses and near the end of life.
- Determine what strategies are most effective to engage persons in CM who are otherwise disengaged from the health care system.

### Intervention

Studies are needed to:

- Assess the impact/importance of the characteristics of the individual serving in the role of case manager (individual traits such as personality, motivation, etc.).
- Evaluate what is the right caseload for case managers.
- Compare the impact of differences in training/education of case managers.
- Compare the impact of case managers from different disciplines (e.g., nurses, social workers, and pharmacists).
- Compare case managers integrated into teams versus case managers working alone.
- Examine the relationship of the case manager with the patients and families and how that relationship impacts outcomes.
- Examine the role of primary care providers in identifying patients who could benefit from CM.
- Assess how to keep case managers focused on the highest-impact components of CM (e.g., supervision and/or incentives).
- Examine the impact of tailoring CM activities based on patient characteristics.
- Compare the effectiveness of standardized CM protocols with more flexible CM protocols.
- Assess whether CM protocols are followed (e.g., fidelity assessments to document whether CM is actually implemented as planned).
- Compare the effectiveness of CM focused on patient education with CM focused on direct patient support activities (e.g., coaching and coordinating care).
- Compare different ways to provide patient education within CM.
- Evaluate the impact of patient-provider interaction techniques or models (e.g., motivational interviewing, coaching, or stages of change) on the effectiveness of CM.
- Examine the link between specific components of CM and specific outcomes (e.g., coordination of care and hospitalization; patient coaching and adherence).
- Examine the role of comprehensive medical management in CM (e.g., ability of case manager to make clinical recommendations or decisions, such as adjusting medications or treatments).
- Examine the role of evaluating the appropriateness of prescribed medications (using existing medication evaluation tools or involving a pharmacist) as part of CM (not simply evaluating adherence).
- Examine the role of including transitional care tools or models as part of CM.
- Compare CM programs that include access to utilization data and the ability to follow patients across settings and episodes with CM that is limited to specific settings or time periods.
- Compare CM programs that vary in intensity.
- Assess potential ways to standardize CM.
- Establish criteria for rating the quality of CM programs (so that quality of CM programs and the effectiveness of programs at different levels of quality can be compared).
- Establish the core components/minimum elements needed for CM.
- Assess the impact of the use of information technology on the effectiveness of CM.
- Examine alternative CM models or new models of care that include CM.
- Compare CM programs with different specific missions or focuses (e.g., focus on preventing major events like hospitalization vs. supporting behavior change).
- Determine the modes of case manager contact (e.g., telehealth, telephone, in-person, home visits, physician's office, etc.) that are most effective.
- Determine the effectiveness of different forms of all of the components of CM (including assessment, evidence-based care planning, patient/family education, engagement/coaching for self-management, coordination of care, proactive monitoring, and integrating with community agencies).
- Determine the effectiveness of aligning CM onset, intensity, composition and duration with the patient's needs.

### Comparator

Studies are needed to:

- Compare CM with other non-CM interventions designed to achieve similar outcomes.
- Compare the effectiveness of different CM components rather than compare CM with usual care.

### Outcomes

Studies are needed to:

- Determine how CM can be made more efficient so that it is either cost neutral or generates savings.
- Assess which resource utilization is the primary outcome for CM.
- Evaluate the impact of CM on families of patients and whether that impact is related to other outcomes.
- Examine other outcomes of CM, such as whether or not it reduces pressure on other parts of the system (i.e., does it make physician's work easier?).
- Interpret pragmatic standards for measuring and reporting relevant outcomes, such as utilization, all stakeholders' costs, quality of care, quality of life, and satisfaction.

### Timing

Studies are needed to:

- Examine whether timing of CM after hospital discharge is associated with effectiveness of CM.
- Evaluate how long patients should be enrolled in CM and what should trigger disenrollment.

### Setting

Studies are needed to:

- Examine different settings and organizations for CM (e.g., role of a single person versus part of primary care).
- Assess how CM can be incorporated into Accountable Care Organizations.
- Compare the effectiveness of CM based in different types of organizations (e.g., insurer, non-profit, hospital-based, primary care provider based, and specialist provider based).
- Examine the effects of different payment approaches (e.g., capitation vs. shared savings vs. fee for service).
- Assess effects of CM in high health services utilization versus low-utilization geographic regions.
- Compare CM in integrated systems with CM in organizations that are not part of an integrated system.
- Examine CM in managed care/health plans/non-academic settings.
- Examine the influence of family caregivers on CM outcomes.

### Other

Studies are needed to:

- Establish pragmatic standards for measuring and reporting CM characteristics and outcomes that should be routinely reported in journal articles/study protocols about CM.
- Establish clear definitions of specific models of CM based, for example, on their components, intensity, and duration.
- Exposition of the pros and cons of various study designs that would be most productive at this stage (e.g., randomized, cluster-randomized, observational, community trials, and qualitative).

## Ranking by Stakeholders

The stakeholder ratings for each topic were summed and divided by the number of respondents to produce a mean score. The mean scores and distributions for all 61 topics are included in Appendix D. There was a distinct separation in the rankings based on both the mean and distributions. Top-tier topics were defined as those with mean over 4.5 (where the maximum possible is 6 and the minimum is 1). Table 3 presents the means and distribution of responses of this top tier of 15 topics.

Table 3 Top-tier research gaps according to stakeholder ratings

Domain | Mean Score | High Priority: Ranked 5-6 % (n)
A. Global
A1. Establish clear definitions of specific models of CM based, for example, on their components, intensity and duration. | 5.67 | 100% (9)
A2. Establish pragmatic standards for measuring and reporting CM characteristics and outcomes that should be routinely reported in journal articles/study protocols about CM. | 5.22 | 78% (7)
A3. Discuss pragmatic standards for measuring and reporting relevant outcomes, such as utilization, all stakeholders' costs, quality of care, quality of life, and satisfaction. | 5.11 | 67% (6)
B. Implementation of CM
B1. Describe how CM can be made more efficient so that it is either cost neutral or generates savings. | 5.11 | 78% (7)
B2. Compare CM programs that include access to utilization data and the ability to follow patients across settings and episodes with CM that is limited to specific settings or time periods. | 5 | 78% (7)
B3. Determine the modes of case manager contact (e.g., telehealth, telephone, in-person, home visits, in physician's office, etc.) that are most effective. | 4.78 | 67% (6)
B4. Compare the impact of differences in training/education of case managers. | 4.56 | 56% (5)
C. Patient Selection/Targeting
C1. Describe the characteristics of patients in CM programs that result in positive outcomes (benefits for patients or positive changes in utilization). | 4.89 | 78% (7)
C2. Examine the impact of tailoring CM activities based on patient characteristics. | 4.75 | 75% (6)
C3. Determine the effectiveness of aligning CM onset, intensity, composition, and duration with the patient's needs. | 4.67 | 67% (6)
D. Evaluation of CM Components
D1. Examine the role of evaluating the appropriateness of prescribed medications (using existing medication evaluation tools or involving a pharmacist) as part of CM (not simply evaluating adherence). | 4.78 | 67% (6)
D2. Examine the role of including transitional care tools or models as part of CM. | 4.78 | 56% (5)
D3. Examine the link between specific components of CM and specific outcomes (e.g., coordination of care and hospitalization; patient coaching and adherence). | 4.56 | 56% (5)
E. Research Design
E1. Describe longitudinal evaluation of the impact of CM, particularly for those with chronic illnesses and near the end of life. | 4.89 | 78% (7)
E2. Exposition of the pros and cons of various study designs that would be most productive at this stage (e.g., randomized, cluster-randomized, observational, community trials, and qualitative). | 4.78 | 67% (6)

CM = case management

These top-tier research topics that would address research gaps were relatively specific and fell into five domains in five areas: (A) global issues related to definitions and standardization in research, (B) details related to the implementation of CM, (C) optimal patient selection or targeting, (D) evaluating components of complex CM interventions, and (E) research design considerations. The domains and specific topics presented in Table 3 are described in more detail in the following text. This description includes a discussion of the potential study designs for each domain as well as examples of research questions with corresponding possible study designs and PICOT (Tables 4–7). These are meant to be illustrative, not inclusive as several different questions and study designs could correspond to each topic.

Table 4 Example specification for global domain

Example Research Question | Proposed Study Design | P | I | C | O | T
What are the core components of a CM intervention? | Survey | Organizations with CM programs | CM programs | None | List and ranking of program components | NA

CM = case management; NA = not applicable; PICOT = population, intervention, comparator, outcome, and timing

Table 5 Example specification for implementation domain

Example Research Question | Proposed Study Design | P | I | C | O | T
What mode of case manager-patient contact is most effective? | Observational study | Complex patients | CM with regular in person contact | CM by telephone with in person contact only at intake | Hospitalization, emergency visits | Long-term followup

CM = case management; PICOT = population, intervention, comparator, outcome, and timing

Table 6 Example specification for targeting domain

Example Research Question(s) | Proposed Study Design(s) | P | I | C | O | T
What is the profile of patients for whom outpatient CM improves outcomes | Trial with risk profiling | Patients enrolled in outpatient CM | Intensive CM | Disease management | Hospitalization, Services utilization, Clinical outcomes for patients stratified by risk profile | Long-term followup of at least 2 years

CM = case management; PICOT = population, intervention, comparator, outcome, and timing

Table 7 Example specification for evaluation of case management components domain

Example Research Question | Proposed Study Design | P | I | C | O | T
Is CM with integrated transitional care more effective? | Head-to-head trial | Patients with complex medical needs who initiate case management after a hospitalization | CM with integrated transitional care | CM without transitional care | Readmission to hospital, Hospitalization for any reason, emergency visits | Long-term at least 2 years

CM = case management; PICOT = population, intervention, comparator, outcome, and timing

## Research Topic Domains and Potential Study Designs

### A Global Domain

Both the CER and the discussion among stakeholders identified that a major challenge in synthesizing the available evidence about CM was the lack of clear definitions and standards. Therefore, in order to approach the synthesis of the available evidence on CM, the CER team developed a definition that was applicable to the available research studies, and this was only partly consistent with definitions developed by other organizations and researchers. With heterogeneity of the CM interventions, it is often hard to be definitive when statements are made about CM based on a synthesis of results across studies of interventions that are believed to be similar (but may actually differ in important ways). Contributing to this lack of clarity is the use of various terms, such as care coordination, care management, disease management, or patient navigation, for interventions that may or may not correspond to CM.

The importance of clarity about the features of CM programs is reflected in the high ranking given to topic A.1 about the need for definitions of CM models. Topics A.2 and A.3 address the need to develop better standards for reporting the applicable research methods in journal publications.

### B Implementation of Case Management Domain

Related, but more specific than the global topics, is a group of topics that focus on key elements of how CM is implemented in practice. The stakeholders discussed the need to study variations in implementation in order to determine how the effectiveness of CM can be maximized. Stakeholders noted that organizations often are looking for an evidence base that will help them decide how to organize and deliver CM and that the existing research often does not help them answer these questions. The highest priority areas rated by the stakeholders include cost effectiveness (topic B.1), data and access across episodes and settings (topic B.2), modes of CM and patient communication (topic B.3), and the training and education needed for effective case managers (B.4). For these topics the primary research goals would be to determine what variations in CM implementation are most likely to result in positive outcomes.

### C Patient Selection/Targeting Domain

A recurring theme in both the CER and the stakeholder discussions was the idea that CM would be more effective if it could be targeted to the patients who need it most and/or tailored to their specific needs. This idea is embodied in three future research topic suggestions that approach this from different angles. Topic C.1 suggests that future studies be used to identify which subgroups of patients are most likely to benefit from CM. This is an exploratory approach that requires studies with diverse patients and large enough sample sizes to allow valid subgroup analysis. The other topics in this domain propose a different approach. Topic C.2 recommends studying CM interventions in which a variety of distinct services or components are available (e.g., medication management, transition care, functional assessments, caregiver support, and coordination of specialist, etc.) and the CM intervention involves customizing CM by using just the components that match the patients needs. Topic C.3 extends this customization from specific services or components to details of CM implementation. In this case stakeholders suggested the need to better understand when different patients need CM and how much they need as well as what they need. These topics suggest that customization may make CM more efficient. The previous published studies of CM commonly included a step in which case managers performed clinical needs assessments for individual patients, and the perspective of the stakeholders was that this function needs a stronger emphasis in future research.

### D Evaluation of Case Management Components Domain

A defining characteristic of CM is that it is a complex, multifaceted intervention. What a case manager does or what is included in a CM intervention includes activities that can be considered separate interventions. An area for future research identified by the stakeholders is to identify the added value obtained by including certain activities in CM. They identified two specific activities, medication assessment (topic D.1) and transitional care (topic D.2), that future research could evaluate as part of CM. The third topic (topic D.3) in this domain is more general in that it proposes that future research should attempt to disaggregate the components of CM interventions that are the subject of study and examine the link between these components and specific outcomes.

### E Research Design Domain

The final two proposed and highly ranked topics address specific approaches to study designs. One of the critiques of the current literature is that the followup period in evaluations of CM may not be appropriate, particularly if the CM intervention is designed to manage chronic illnesses or end of life care. Topic E.1 is directly related to this issue and calls for longitudinal studies. Topic E.2 is more general and grew out of the discussion by the stakeholders of the CER results. While the CER reported on a relatively large body of literature, the stakeholders felt that this literature does not answer Key Questions that are important to clinicians, patients, and policymakers. Different research might need to employ a wider variety of methods. For example, it was suggested that a randomized trial that compares patients assigned to CM to others assigned to usual care is unlikely to help answer questions about how best to implement CM. These questions might be answered through case studies or comparisons of practices (clusters) that take different approaches to implementing CM.

This input was used to inform the proposed study designs provided as examples above and in Table 9 below. However, they were also retained as topics for future research because they suggest that methodological research and development is needed to advance the field. While the stakeholders agreed that innovative approaches are needed, the methods needed to answer the questions raised in the other domains are well developed or easily available to researchers.

Table 9 Topics for future research, recent and ongoing studies, and potential study designs

Domain | Specific Top-Tier Topics | Applicable PICOT Gap | Recent Studies | Ongoing Research | Potential Study Designs
A. Global | A.1. Establish clear definitions of specific models of CM based, for example, on their components, intensity and duration. | Other | Hughes, 2011^8^ Reilly, 2011^10^ Ross, 2011^11^ | Morales-Asencio, 2010^16^ | Descriptive studies:; - Expert consensus.; - CM Program Case Studies.; - Practice/Policy Analysis.; - Surveys.
A. Global | A.2. Establish pragmatic standards for measuring and reporting CM characteristics and outcomes that should be routinely reported in journal articles/study protocols about CM. | Other | | | Descriptive studies:; - Expert consensus.; - Surveys.
A. Global | A.3. Studies with pragmatic standards for measuring and reporting relevant outcomes, such as utilization, all stakeholders' costs, quality of care, quality of life, and satisfaction. | Outcomes | | | Descriptive studies:; - Expert consensus.; - Surveys.
B. Implementation of CM | B.1. Studies of how CM can be made more efficient so that it is either cost neutral or generates savings. | Outcomes | Baker, 2011^5^ Hines, 2011^7^ Peikes, 2012^9^ Ross, 2011^11^ | King's Fund, 2012^20^ Koopmans, 2012^21^ Raven, 2012^22^ | Trials or observational studies that collect relevant:; - Cost and resource utilization data as outcomes.; - Sufficient information about the intervention in order to assess the factors that affect efficiency and cost-effectiveness.
B. Implementation of CM | B.2. Studies that compare CM programs that include access to utilization data and the ability to follow patients across settings and episodes with CM that is limited to specific settings or time periods. | Intervention | | | Trials or observational studies. Program case studies.
B. Implementation of CM | B.3. Studies to determine the modes of case manager contact (e.g., telehealth, telephone, in-person, home visits, in physician's office, etc.) that are most effective. | Intervention | Brown, 2012^6^ Peikes, 2012^9^ | | Trials or observational studies. Program case studies.
B. Implementation of CM | B.4. Studies that compare the impact of differences in training/education of case managers. | Intervention | | Freund, 2011^23^ NCMN, 2012^27^ | Trials or observational studies. Program case studies.
C. Patient Selection/Targeting | C.1. Studies that describe the characteristics of patients in CM programs that result in positive outcomes (benefits for patients or positive changes in utilization). | Intervention | Reilly, 2011^10^ | Egede, 2011^24^ | Subgroup analysis or risk profiling as part of trials or observational studies.
C. Patient Selection/Targeting | C.2. Studies that examine the impact of tailoring CM activities based on patient characteristics. | Intervention | | Crane, 2012^26^ Freund, 2010^19^ Versnel, 2011^25^ | Head-to-head trials or observational studies that compare different approaches to CM.
C. Patient Selection/Targeting | C.3. Studies that determine the effectiveness of aligning CM onset, intensity, composition and duration with the patient's needs. | Intervention | | | Head-to-head trials or observational studies that compare different approaches to CM.
D. Evaluation of CM Components | D.1. Studies that examine the role of evaluating the appropriateness of prescribed medications (using existing medication evaluation tools or involving a pharmacist) as part of CM (not simply evaluating adherence). | Intervention | Brown, 2012^6^ Peikes, 2012^9^ | Morales-Asencio, 2010^16^ | Head-to-head trials or observational studies that compare CM with and without medications management.
D. Evaluation of CM Components | D.2. Studies that examine the role of including transitional care tools or models as part of CM. | Intervention | Brown, 2012^6^ Peikes, 2012 9 | | Head-to-head trials or observational studies that compare CM with and without transitional care.
D. Evaluation of CM Components | D.3. Studies that examine the link between specific components of CM and specific outcomes (e.g., coordination of care and hospitalization; patient coaching and adherence). | Intervention | Baker, 2011^5^ Peikes, 2012^9^ Reilly, 2011^10^ Ross, 2011^11^ Wade, 2011^12^ | Bachmann-Mettler, 2011^18^ Freund, 2010^19^ Kings Fund, 2012^20^ Koopmans, 2012^21^ Zwarenstein, 2011^17^ | Head-to-head trials or observational studies that compare CM with different components such as factorial designs or studies with multiple treatment arms.
E. Research Design | E.1. Studies that describe longitudinal evaluation of the impact of CM, particularly for those with chronic illnesses and near the end of life. | Population | | | Trials with long-term followup. Observational studies; - Registry Studies.; - Retrospective studies of several years of records.
E. Research Design | E.2. Exposition of the pros and cons of various study designs that would be most productive at this stage (e.g., randomized, cluster-randomized, observational, community trials, qualitative). | Other | | | Methodological research. Expert consensus beyond what could be done within the scope of this project.

CM = case management; NCMN = National Case Management Network; PICOT = population, intervention, comparator, outcome, and timing Empty cells denote no studies found.

## Responses to Open-Ended Items

The stakeholder questionnaire included optional open-ended items. (The questions and layout are included in Appendix B.) Not all stakeholders provided responses to open-ended items. For this reason they were used to inform this report, but all of these open-ended responses are not reported separately. The one exception is the open-ended item that asked what should be reported and/or measured in all studies of CM. Eight of nine stakeholders provided responses to this question and the stakeholder responses are categorized and listed in Table 8. All the responses we received and how they were coded to construct the categories in the table are included in Appendix E.

Table 8 Stakeholder responses to item about what should be reported and/or measured in all case management studies

Categories of What Should Be Reported/Measured | Stakeholder Responses
Implementation specifics | - Intensity/duration; - Termination criteria; - Mode of contact; - How the contact is made and what is done at each contact
Caseload | - Caseload
Case manager characteristics | - Identification of all members of the team and roles/responsibilities; - Background/training of case managers
CM description/components | - Greater specificity of all aspects of the interventions; - Approach to education; - Care plan details; - Medication management; - Family caregiver interventions
Environment/context | - Interaction with usual care providers; - Implementation process/challenges; - How CM fits into the overall design of the clinic; - Type and frequency of interactions between and among team members with primary care provider
Cost | - All program costs; - The cost outcome; - Return on investment
Patient selection/characteristics | - Patient selection criteria; - Identification of population targeted for CM
Outcomes: general | - Major system impact of CM; - Effects on all stakeholders; - Goals
Clinical outcomes | - The clinical outcome
Patient satisfaction | - Patient satisfaction

CM = case management

It is not surprising that these responses overlap with the domains of the topics proposed for future research. The literature scan also confirmed that these are key topics and are the subject of ongoing research and policy projects (more information is provided in that section below). However, the stakeholders strongly endorse the need for these efforts, and there was agreement that better information in both study protocols and reports is essential to all future research on CM.

## Literature Scan Results

The searches of bibliographic databases produced 1,219 citations (see search strategies in Appendix C). This included 949 abstracts and articles reporting ongoing and recently published research, 141 descriptions of clinical trials from registries, and 129 project descriptions from grant databases. Most were outside the scope of the original CER or did not address potential topics for future research. After examination of full-text and followup on registry entries we identified 10 studies published after the period covered by the search for the CER and 12 ongoing studies or projects that either had published protocols or were listed in a trials registry.

As the literature scan was conducted at the same time as the stakeholder engagement, the search was broader than the topics identified; however, almost all studies and projects matched the domains if not the exact specific topic.

### Recent Studies

Selected information about the recent studies identified in the literature scan is provided in Appendix F. The studies were all published in 2011 or 2012. Eight of the studies5-12 addressed one or more of the issues/topics prioritized by the stakeholders for future research. Two studies13, 14 met the inclusion criteria for the CER in that they evaluated the effectiveness of outpatient CM but they did not address any of the identified topics for evidence gaps. The eight studies addressed 9 of the 15 top-tier topics and topics in all the domains except Research Design. The most common domain for these study topics was the link between specific components of CM and specific outcomes, which was the subject of five studies.5, 9-12

While the Research Design domain was not addressed directly in these studies, an examination of the types of studies reveals the frequent use of mixed methods in their study designs. One study was a randomized trial12 and two studies involve re-examination or supplemental analysis of a previously published randomized trial that was included in the CER.6, 9 One study used matched controls in a pre-post design,15 two combined surveys and case studies,7, 8 one combined observational data with survey data,10 and one combined case studies with a literature review.11

### Ongoing Studies

Information about the 12 relevant, ongoing studies is included in Appendix G. These studies were identified via published protocols, entries in trial registries, or descriptions in articles that led to more detailed information. As these are studies in progress, less information is often available than may be available for a completed study. The identified studies and project have a range of anticipated end dates from 2012 to 2015. In some cases we were unable to locate information on when the study was expected to be completed.16, 17

The ongoing studies addressed 6 of the 15 top-tier topics included some topics in all domains except Research Design. The most common topics were the link between specific components of CM and specific outcomes, which was the topic of five ongoing studies17-21 and making CM more efficient or cost effective, which was the focus of three.20-22

The ongoing studies contained more randomized trials than the recent studies we identified, but this is likely to be the result of including trial registries in our searches and the fact that registration/reporting of protocols for nonrandomized studies is less common. Six of the 12 ongoing studies were randomized trials including two cluster randomized trials22, 23 and four in using randomization at the level of individual patients.18, 24-26 We also identified protocols for two systematic reviews17, 19 and one prospective cohort study.21 Three of the studies or projects in progress involved multiple qualitative methods including interviews, focus groups, text analyses, and expert consensus.16, 20, 27

## Synthesis of Results: Foundation for a Future Research Agenda

This FRN project identified significant and essential questions that remain unanswered. Table 9 combines the domains and specific topics identified by stakeholders, recent studies, and ongoing research and suggested potential study designs.

During the Webinars the CER author and stakeholders discussed the idea that perhaps there already has been enough research on CM based on the currently defined clinical models and that future research should focus on developing new clinical paradigms. Specifically the participants agreed that more research – either trials or observational studies – that compare CM to usual care and treat CM as a single, uniform intervention (“black box”) are not needed. Rather, what is needed are studies that (a) compare CM to other care models designed to correct for fragmented care; (b) “unpack” the black box of CM interventions by both specifying what the intervention involves and linking specific components to specific outcomes; and (c) studies that use different research approaches to obtain information about how best to implement CM in practice. The domains, topics, and potential study designs proposed by this FRN project are intended to help researchers, funders, and other stakeholders focus future efforts. The project results support a research agenda that will give clinicians and policymakers the information they need to decide when CM is an appropriate intervention and how it can be implemented so that it promotes high-quality and cost-effective care.