# References

1 Institute of Medicine. Crossing the quality chasm: A new health system for the 21st century. Washington DC. The National Academies Press. 2001.
2 Wolff JL, Starfield B, Anderson G. Prevalence, expenditures, and complications of multiple chronic conditions in the elderly. Arch Intern Med. November. 11. 2002;162(20):2269-76. [pmid: 12418941].
3 Berry-Millett R, Bodenheimer TB. Care management of patients with complex health care needs. Synth Proj Res Synth Rep. December. 2009;19:1-36. [pmid: 22052205].
4 Hickam DH, Weiss JW, Guise JM, et al. Outpatient Case Management for Adults with Medical Illness and Complex Care Needs. Comparative Effectiveness Review No. 99. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 13-EHC031-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
5 Baker LC, Johnson SJ, Macaulay D, et al. Integrated telehealth and care management program for Medicare beneficiaries with chronic disease linked to savings. Health Affairs. Sep. 2011;30(9):1689-97. [pmid: 21900660].
6 Brown RS, Peikes D, Peterson G, et al. Six features of Medicare coordinated care demonstration programs that cut hospital admissions of high-risk patients. Health Affairs. June. 1. 2012. 2012;31(6):1156-66. [pmid: 22665827].
7 Hines D. Using quality improvement principles and concept analysis to refine the role of HIV case management. Care Management. 2011;17(5):7.
8 Hughes J, Reilly S, Berzins K, et al. Emergent Approaches to Care Coordination in England: Exploring the Evidence From Two National Organizations. Care Management Journals. 2011;12(4):194-201. [pmid: 23214241].
9 Peikes D, Peterson G, Brown RS, et al. How Changes In Washington University's Medicare Coordinated Care Demonstration Pilot Ultimately Achieved Savings. Health Affairs. June. 1. 2012. 2012;31(6):1216-26. [pmid: 22665833].
10 Reilly S, Abell J, Brand C, et al. Case management for people with long-term conditions: impact upon emergency admissions and associated length of stay. Primary Health Care Research & Development. Jul. 2011;12(3):223-36. [pmid: 21798120].
11 Ross S, Curry N, Goodwin N. Case management: what it is and how it can best be implemented. London. The King's Fund. 2011. www.kingsfund.org.uk/sites/files/kf/Case-Management-paper-The-Kings-Fund-Paper-November-2011.pdf.
12 Wade MJ, Desai AS, Spettell CM, et al. Telemonitoring with case management for seniors with heart failure. Am J Manag Care. Mar. 2011;17(3):e71-9. [pmid: 21504262].
13 Mayo NE, Scott S. Evaluating a complex intervention with a single outcome may not be a good idea: an example from a randomised trial of stroke case management. Age Ageing. Nov. 2011;40(6):718-24. [pmid: 22016344].
14 Rinke ML, Dietrich E, Kodeck T, et al. Operation care: a pilot case management intervention for frequent emergency medical system users. Am J Emerg Med. Feb. 2012;30(2):352-7. [pmid: 21269790].
15 Majumdar SR, Johnson JA, Bellerose D, et al. Nurse case-manager vs multifaceted intervention to improve quality of osteoporosis care after wrist fracture: randomized controlled pilot study. Osteoporos Int. Jan. 2011;22:223-30. [pmid: 20358359].
16 Morales-Asencio JM, Martin-Santos FJ, Morilla-Herrera JC, et al. Design of a case management model for people with chronic disease (Heart Failure and COPD). Phase I: modeling and identification of the main components of the intervention through their actors: patients and professionals (DELTA-icE-PRO Study). BMC Health Services Research. 2010;10:324. [pmid: 21126369].
17 Zwarenstein M, Reeves S, Straus SE, et al. Case management: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. (c. 2011). 2000;(4):CD002797.
18 Bachmann-Mettler I, Steurer-Stey C, Senn O, et al. Case management in oncology rehabilitation (CAMON): the effect of case management on the quality of life in patients with cancer after one year of ambulant rehabilitation. a study protocol for a randomized controlled clinical trial in oncology rehabilitation. Trials. 2011;12:103. [pmid: 21526985].
19 Freund T, Kayling F, Miksch A, et al. Effectiveness and efficiency of primary care based case management for chronic diseases: rationale and design of a systematic review and meta-analysis of randomized and non-randomized trials [CRD32009100316]. BMC Health Services Research. 2010;10:112. [pmid: 20459654].
20 The Kings Fund. Co-ordinated care for people with complex chronic conditions. The Kings Fund. 2012. www.kingsfund.org.uk/current_projects/coordinated_care/coordinated_care.html. Aug 29, 2012.
21 Radboud University, ZonMw: The Netherlands Organisation for Health Research and Development, Dutch Healthcare Authority, Health insurances CZ, Health Insurances UVIT, City of Nijmegen. The CareWell-programme for Community-dwelling Frail Elderly Persons. ClinicalTrials.gov. [Internet]. Bethesda (MD). National Library of Medicine (U.S.). 2011. ClinicalTrials.gov/show/NCT01499797. June 14, 2012.
22 New York City Health and Hospitals Corporation, New York City Health and Hospitals Corporation, New York State Department of Health. A Patient Centered Intervention to Improve Health and Reduce Medicaid Costs. ClinicalTrials.gov. [Internet]. Bethesda (MD). National Library of Medicine (U.S.). 2012. ClinicalTrials.gov/show/NCT01602848. June 14, 2012.
23 Freund T, Peters-Klimm F, Rochon J, et al. Primary care practice-based care management for chronically ill patients (PraCMan): study protocol for a cluster randomized controlled trial [ISRCTN56104508]. Trials. 2011;12:163. [pmid: 21714883].
24 Egede LE, Strom JL, Fernandes J, et al. Effectiveness of technology-assisted case management in low income adults with type 2 diabetes (TACM-DM): study protocol for a randomized controlled trial. Trials. 2011;12:231. [pmid: 22014122].
25 Versnel N, Welschen LMC, Baan CA, et al. The effectiveness of case management for comorbid diabetes type 2 patients; the CasCo study. Design of a randomized controlled trial. BMC Fam Prac. 2011;12:68. [pmid: 21729265].
26 University of Washington, National Institutes of Health (NIH), National Institute of Mental Health (NIMH), National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS). Randomized Controlled Trial Using Patient Reported Outcomes and Care Managers to Improve HIV Medication Adherence in Routine Clinical Care. ClinicalTrials.gov. [Internet]. Bethesda (MD). National Library of Medicine (U.S.). 2012. ClinicalTrials.gov/show/NCT01505660. June 14, 2012.
27 National Case Management Network (Canada). Canadian Core Competencies for Case Management Providers (Editorial Draft). National Case Management Network. 2012.