# Methods

This project involved two main activities: stakeholder engagement and a literature scan. These activities expanded on the FRNs identified by the authors of the CER. Stakeholders were engaged to develop a detailed list of relevant topics for future research and then to prioritize these topics. A literature scan was used to identify studies completed since the CER was completed as well as ongoing research and initiatives related to gaps in the evidence base.

The protocol and goals for this project were reviewed by the Institutional Review Board (IRB) at Oregon Health & Science University. The IRB determined that this project did not meet the definition of human subject research per 45 CFR 46.102(f) (IRB #: IRB00008449).

## Identification of Evidence Gaps

We began with the evidence gaps described in the CER report. Next, the project team reviewed summaries of the topic refinement and technical expert panel discussions that informed the CER. We also received input from the lead author of the original report, who was a member of the FRNs project team. From these sources we developed a preliminary list of topics and discussion points to pursue with the stakeholders. Finally, additional evidence gaps and potential research topics were generated by stakeholders during two Webinars and one individual interview. The project team worked together to organize all the evidence gaps into unique topics or questions and to categorize these according to the PICOTS framework. Stakeholders then provided additional feedback on the categorized topics list.

Topics considered relevant for this FRN project included those that fit within the scope of the original CER. Also considered relevant were topics raised during the planning and execution of the CER, including topics related to the identification and synthesis of evidence on the effectiveness of CM (such as efforts to establish definitions of models of CM).

## Engagement of Stakeholders

### Identifying and Recruiting Stakeholders

In order to have a variety of input, the team identified and recruited stakeholders from different perspectives. These stakeholders included clinicians, researchers, research funders, policymakers, and patient advocates. Our main priority was to have at least one representative from each stakeholder category so that the discussion and prioritization of research gaps incorporated multiple stakeholder perspectives.

Recruitment occurred during May and June 2012. We sought to create a group that could interact and collectively provide an assessment of the research needed to advance health policy and practice related to CM.

The research team sent written invitations to the potential stakeholders/participants (see Appendix A). The letters included a brief overview of the project, explained what participation would entail, and provided contact information in case there were any questions. Followup emails were sent as needed, and reminder phone calls were made in some cases. In compliance with Federal guidelines we did not aim to recruit more than nine non Federal employees. Participation at all stages was voluntary, and participants were free to decline to participate in any activity or decline to answer any specific question.

Once individual stakeholders agreed to participate, a member of the research team contacted them with further details. Stakeholders were offered the choice of two dates to attend a Webinar. Accommodations for individual phone calls were made in the case that interested stakeholders could not attend either of the Webinars.

### Disclosure and Evaluation of Conflicts of Interest

All participating stakeholders received the “EPC Conflict of Interest Disclosure Form.” All stakeholders completed and returned the disclosure before participating in Webinars or interviews. The research team and the Agency for Healthcare Research and Quality (AHRQ) Task Order Officer reviewed disclosures from the stakeholders who agreed to participate and did not identify any financial or professional/business conflicts that would preclude any of the stakeholders from participating in the project.

### Stakeholder Engagement

The research team hosted two Webinars on different days and times in order to accommodate stakeholder schedules. Materials were sent to all stakeholders before the scheduled Webinars. These materials included the draft executive summary of the CER, the protocol for this FRN project, instructions for accessing Adobe® Connect™, and a copy of the PowerPoint® slides to be used for the Webinars. The research team, including the principal investigator of the CER, hosted the Webinars via Adobe Connect. Audio recordings were made after the participants provided verbal permission to record the discussions.

There were three main aims of the Webinars: (1) to provide an overview of the CER; (2) to provide further explanation of the FRNs project goals, introduce the Effective Health Care (EHC) Program, and answer any stakeholder questions; and (3) to engage stakeholders to identify research needs and augment the gaps identified in the CER. Each Webinar lasted approximately 90 minutes and consisted of approximately the same content, though the discussion varied somewhat according to the expertise and interests of the participants at the two sessions. The Webinars were facilitated by one investigator, with each investigator presenting a portion of the background material, answering stakeholder questions, and asking followup questions of the stakeholders as needed to clarify topics they suggested.

At the end of each Webinar, we informed stakeholders that they could contact us with any further comments or questions if they desired. We informed them that we would contact them shortly with a list of research gap topics for their review and revision so that they could provide comments and additions before we created the online questionnaire. Because one stakeholder could not attend either Webinar, we scheduled an individual telephone call, during which we presented the same information reviewed in the Webinars and solicited feedback.

The audio portion of the Webinars and telephone call were professionally transcribed. Team members reviewed the transcripts to make sure that all stakeholder input was considered and all topics identified during the discussion were included in the draft list. We then created a list of research gaps that included those listed in the CER as well as those generated through the Webinars. Prior to creating the questionnaire used to rank the topics, all stakeholders received the list of potential topics and were asked to submit any amendments or additions. Some replied with additions which were included in the questionnaire.

### Prioritization

Using the list of topics for evidence gaps developed with the stakeholders, the research team created an online questionnaire (see Appendix B) using SurveyMonkey®. To assess comprehensiveness and usability we piloted the instrument with a small convenience sample of five individuals. We incorporated suggestions from pilot participants before sending the final link to stakeholders. Each stakeholder who participated in the Webinars or telephone interview was invited to respond to the questionnaire. Reminders were sent via email as necessary.

The questionnaire consisted of three parts. In the first section respondents were asked to self-identify their perspective and were provided instructions for the questionnaire. Stakeholders were instructed that throughout the questionnaire they should keep in mind the EHC program priorities of importance, desirability of new research, feasibility, and potential impact while ranking each evidence gap topic. The second section listed 61 topics identified as potential research gaps. For presentation purposes, we grouped topics together by the PICOTS that they best addressed as well as an “other” section for those that did not fall into a particular PICOTS category. Stakeholders were asked to rate the priority of each gap for future research on a scale of 1 to 6, with 1 indicating lowest priority and 6 indicating highest priority. Respondents also could provide additional text comments at the end of each section. The final section consisted of open-ended questions where stakeholders were asked how future research on CM should be different from current and previous research, which components of CM interventions should be reported in all studies, what a standardized definition of CM should include, and a request for information about any related ongoing or recently published studies.

### Analysis

From the priority ratings selected by each respondent, mean values for each topic were computed. The topics were then sorted by the mean rating to identify the top tier of evidence gaps. The distribution of the responses was also reviewed, that is the number of times they appeared in the highest, middle, and lowest priorities (rated 5-6, 3-4, and 1-2, respectively). Because there was a clear break at 15 items and these 15 corresponded to a small number of domains, we did not engage in a second round of prioritization. For the open-ended responses, we used a thematic analysis method to group these into categories.

## Identification of Recently Completed and Ongoing Studies

A research librarian conducted searches to identify research funding, ongoing research, and recently completed research. The original search strategies used for the CER were repeated for the time period August 2011-June 2012. Searches were conducted using MEDLINE, the Cochrane Central Registry of Controlled Trials (CCRCT), the Cochrane Database of Reviews of Effects (DARE), and the Cochrane Database of Systematic Reviews. Unpublished materials were identified by searching clinical trial registries (ClinicalTrials.gov, Current Controlled Trials, Clinical Trial Results, World Health Organization [WHO] Trial Registries) and governmental grant databases (NIHRePORTER, HSRProj, and AHRQ GOLD), as well as a U.S. private and community foundations database (for detailed search strategy see Appendix C). Titles and abstracts were triaged by two team members, with full-text pulled and reviewed if at least one team member thought the study might be related to the CER Key Questions or if the study appeared to address information gaps identified in the review or by the stakeholders. Studies retained after full-text review were then matched with stakeholder identified research priorities.

## Research Question Development and Research Design Considerations

For the top-tier FRNs we identified specific questions and research designs based on input from the stakeholders. At several points stakeholders stated that multiple approaches or types of research were needed in order to provide answers that were not available from previous research. Additional factors in proposing research designs to be considered included: the feasibility of the design; the resources required; ethical considerations, particularly in terms of what can be used as a comparator; and the relevance to future implementation in health services delivery and policy.