# Executive Summary

## Background

In 2010, the Agency for Healthcare Research and Quality (AHRQ) charged the Oregon Evidence-based Practice Center with conducting a Comparative Effectiveness Review (CER)1 to assess the effectiveness of outpatient case management as an intervention strategy for chronic illness management.

The Key Questions the review addressed were:

Key Question 1. In adults with chronic medical illness and complex care needs, is case management effective in improving:

1a Patient-centered outcomes, including mortality, quality of life, disease-specific health outcomes, avoidance of nursing home placement, and patient satisfaction with care?
1b Quality of care, as indicated by disease-specific process measures, receipt of recommended health care services, adherence to therapy, missed appointments, patient self-management, and changes in health behavior?
1c Resource utilization, including overall financial cost, hospitalization rates, days in the hospital, emergency department use, and number of clinic visits (including primary care and other provider visits)?

Key Question 2. Does the effectiveness of case management differ according to patient characteristics, including but not limited to: particular medical conditions, number or type of comorbidities, patient age and socioeconomic status, social support, and/or level of formally assessed health risk?

Key Question 3. Does the effectiveness of case management differ according to intervention characteristics, including but not limited to: practice or health care system setting; case manager experience, training, or skills; case management intensity, duration, and integration with other care providers; and the specific functions performed by case managers?

The analytic framework (Figure A) outlines the targeted population, interventions, and outcomes for the review.

Figure A Original analytic framework from Comparative Effectiveness Review

Note: Numbers refer to Key Questions.

This figure depicts the analytic framework that outlines the target population, interventions, and outcomes considered in the review. The target population includes adults with medical illness and complex care needs in outpatient settings.The intervention is case management. Patient health outcomes include overall quality of care, disease-specific quality of care, quality of life, patient satisfaction, morbidity and mortality. Resource utilization outcomes include overall cost, hospitalization rates and emergency department use. Quality of care process measure outcomes include adherence to therapy, missed appointments, patient self-management, change in health behavior, disease-specific processes of care, and physician or case manager satisfaction.

After synthesizing the results from 109 studies, the CER concluded that case management (CM) interventions matching the review's definition and scope had limited impact on patient-centered outcomes, quality of care, and resource utilization among patients with chronic medical illness. The review did identify some clinical settings in which CM had positive (though modest) effects on these outcomes.

The CER also identified both limitations of existing studies and gaps in the literature. Based on these, the CER underscores how these limitations and gaps restrict the ability of the existing research literature to answer important questions about CM.

The limitations are related to a fundamental challenge the CER faced—the multiplicity of roles and the variability of day-to-day activities in different CM interventions. This lack of specification made it difficult to: (1) isolate components of CM that might contribute to its effectiveness and (2) be confident that indirect comparisons across studies are comparing equivalent interventions.

The research gaps identified in the CER are summarized below and are organized according to the most relevant element of the PICOT (population, intervention, comparator, outcome, and timing) framework. Contextual issues noted in the CER are included as well.

Population | - Studies that assess the use of risk assessment tools for choosing candidates and determining which patient subgroups achieve the greatest benefits from CM.; - Better specification of populations receiving CM.
Intervention | - Studies to assess the intensity of CM including whether the frequency of CM contacts, length and content of contacts, and approaches to followup of problems have an effect on patient outcomes.; - Studies to determine when CM should emphasize direct support compared with patient education.; - Better specification of the components of CM interventions.
Comparator | - Studies to determine the effectiveness of CM delivered by different case managers.; - Studies to assess the potential to standardize CM and the importance of choosing individuals to implement CM.; - Studies that compare CM to other interventions designed to achieve similar outcomes.
Outcome | - None noted.
Timing | - Studies needed to determine the appropriate length of time for patients to receive CM in order to achieve the best outcomes.
Contextual Issues | - Understanding of specific areas that should be explicit in reporting the characteristic of case managers and the specifics of the CM intervention, including training received by case managers, case manager experience, specific functions of case managers and the distribution of effort devoted to different activities, modes of contact (e.g., clinic visits, home visits, and telephone calls), average caseload, relationship to other health care providers, and the use of protocols, guidelines, and information technology.

There is a relationship between the limitations of the literature and the evidence gaps. Because CM is often poorly defined and sufficient details about the patient population and the intervention are often not provided, current research evidence cannot answer questions about how to best target CM interventions. That is, which patients are most likely to benefit from specific components of CM is not clear.

## Methods

To develop an agenda for future research, we began with the limitations and gaps identified in the CER report. We reviewed summaries of the topic refinement and technical expert panel discussions that informed the CER. The lead author of the original report was also a member of the Future Research Needs (FRN) project team. Based on these sources we developed a preliminary list of topics and discussion points.

We presented the CER results and the preliminary list to stakeholders via Webinars and phone discussions and asked them to provide feedback. Using this list the research team created an online questionnaire using SurveyMonkey®. We asked stakeholders to rate the importance of each proposed topic for future research on a scale of 1 to 6 with 1 indicating lowest priority and 6 indicating highest. Stakeholders were instructed to consider the Effective Health Care (EHC) program priorities of importance, desirability of new research, feasibility, and potential impact while ranking each evidence gap topic. We also used open-ended questions to ask stakeholders how future research on CM should be different from research conducted to date, which components of CM interventions should be reported in all studies, and what a standardized definition of CM should include.

We calculated the means of the stakeholder ratings of the topics, and the 15 with the highest overall mean rating were classified as the top-tier research gaps. Responses to the open-ended question answered by all but one of the stakeholders were coded by two team members separately who then reconciled differences and developed the final coding of the responses.

In addition to the stakeholder input, we also searched for ongoing research and recently completed studies. Using the original search strategies for the CER, a research librarian conducted searches of MEDLINE, the Cochrane Central Registry of Controlled Trials, the Cochrane Database of Reviews of Effects, and the Cochrane Database of Systematic Reviews for the time period August 2011-June 2012. Unpublished materials were identified by searching clinical trial registries (ClinicalTrials.gov, Current Controlled Trials, Clinical Trial Results, World Health Organization [WHO] Trial Registries) and governmental grant databases (NIHRePORTER, HSRProj, and AHRQ GOLD), as well as a U.S. private and community foundations database. Full text articles were retrieved if the studies related to the CER Key Questions or if the study appeared to address gaps identified in the review or by the stakeholders. Studies retained after full-text review were then matched with stakeholder identified research priorities. Finally, for the top-tier FRNs that stakeholders prioritized, we identified potential research designs based on input from the stakeholders.

## Results

Nine of 21 invited stakeholders participated in one of two Webinars or a telephone interview and in prioritizing topics. Each stakeholder signed conflict of interest forms and none indicated any conflicts that would preclude them from taking part in the project.

The research team invited stakeholders to participate based on their perspectives. The stakeholders consisted of the following team-identified perspectives: two clinicians/researchers; one research funder; three policy makers, two patient advocates, and one representative of social work/social services. Because stakeholders often bring several perspectives to a task, we asked them to self report their primary perspective. Four of the nine self-identified perspectives matched those assigned by the research team. One stakeholder was invited as a policymaker but self-identified as a researcher; the remaining four opted for the “other” category and provided a category not specifically defined in the recruitment process.

Based on stakeholder input and review of the CER, we generated a list of 61 potential topics for future research. The stakeholder ratings for each topic were evaluated, and there was a distinct separation in the rankings based on both the means and distributions of ratings. Top-tier topics were defined as those with a mean over 4.5 (maximum possible was 6 and the minimum was 1). These top-tier research topics that address current research gaps are relatively specific and fall into five domains in five areas: (A) global issues related to definitions and standardization in research; (B) details related to the implementation of CM; (C) optimal patient selection or targeting; (D) evaluating components of complex CM interventions; and (E) research design considerations. Table A presents the means and number of stakeholders who gave the topic a high rating and organizes the specific topics by these domains.

Table A Top-tier research gaps according to stakeholder ratings

Domain | Mean Score | High Priority: Ranked 5-6 % (n)
A. Global
A1. Establish clear definitions of specific models of CM based, for example, on their components, intensity and duration. | 5.67 | 100% (9)
A2. Establish pragmatic standards for measuring and reporting CM characteristics and outcomes that should be routinely reported in journal articles/study protocols about CM. | 5.22 | 78% (7)
A3. Discuss pragmatic standards for measuring and reporting relevant outcomes, such as utilization, all stakeholders' costs, quality of care, quality of life, and satisfaction. | 5.11 | 67% (6)
B. Implementation of CM
B1.Describe how CM can be made more efficient so that it is either cost neutral or generates savings. | 5.11 | 78% (7)
B2. Compare CM programs that include access to utilization data and the ability to follow patients across settings and episodes with CM that is limited to specific settings or time periods. | 5 | 78% (7)
B3. Determine the modes of case manager contact (e.g., telehealth, telephone, in-person, home visits, in physician's office, etc.) that are most effective. | 4.78 | 67% (6)
B4. Compare the impact of differences in training/education of case managers. | 4.56 | 56% (5)
C. Patient Selection/Targeting
C1. Describe the characteristics of patients in CM programs that result in positive outcomes (benefits for patients or positive changes in utilization). | 4.89 | 78% (7)
C2. Examine the impact of tailoring CM activities based on patient characteristics. | 4.75 | 75% (6)
C3. Determine the effectiveness of aligning CM onset, intensity, composition, and duration with the patient's needs. | 4.67 | 67% (6)
D. Evaluation of CM Components
D1. Examine the role of evaluating the appropriateness of prescribed medications (using existing medication evaluation tools or involving a pharmacist) as part of CM (not simply evaluating adherence). | 4.78 | 67% (6)
D2. Examine the role of including transitional care tools or models as part of CM. | 4.78 | 56% (5)
D3. Examine the link between specific components of CM and specific outcomes (e.g., coordination of care and hospitalization; patient coaching and adherence). | 4.56 | 56% (5)
E. Research Design
E1. Describe longitudinal evaluation of the impact of CM, particularly for those with chronic illnesses and near the end of life. | 4.89 | 78% (7)
E2. Exposition of the pros and cons of various study designs that would be most productive at this stage (e.g., randomized, cluster-randomized, observational, community trials, and qualitative). | 4.78 | 67% (6)

CM = case management

The searches of bibliographic databases produced 1,219 citations including 949 abstracts of articles reporting ongoing and recently published research, 141 descriptions from clinical trial registries, and 129 project descriptions from grant databases. Of these, we identified 10 studies published after the CER search period and 12 ongoing studies or projects that either had published protocols or were listed in a trials registry. The recently completed studies were published in 2011 or 2012. Eight of them address one or more of the issues/topics prioritized by the stakeholders for future research while two met inclusion criteria for the CER but did not match up with any of the top-tier evidence gaps. The twelve ongoing studies have a range of anticipated end dates from 2012 to 2015. We were unable to determine when two studies were expected to be completed.

The recently completed and ongoing studies addressed at least some component of nine of the top-tier research topics. Three recent studies and one ongoing project correspond to establishing clear definitions of specific models of CM. Four completed and two ongoing studies address how CM can be made more cost efficient. Two recently completed studies focus on determining the modes of case manager contact that are most effective. Two ongoing projects compare the impact of differences in case manager training. Three ongoing studies examine the impact of tailoring CM activities based on patent characteristics. Two recently completed studies and one ongoing study examine the role of evaluating appropriateness of prescribed medication. The same two recently completed studies examine the role of including transitional care models as part of CM. Finally, five completed and four ongoing studies examine the link between specific components of CM and outcomes.

During the Webinars the CER author and stakeholders discussed the idea that future research should focus on developing new clinical paradigms. For this reason, we propose study designs that may help “unpack” the “black box” of CM interventions. In addition to randomized trials and observational studies, we propose research designs of descriptive studies including surveys, expert consensus, program case studies, and practice/policy analysis. Finally, the proposed research agenda includes subgroup analysis and the collection of sufficient information about the intervention when researchers conduct trials or observational studies. For more detail on identified recent and ongoing studies and proposed study designs, please see the full report.

## Discussion

The CER concludes and stakeholders agreed that studies that (1) compare CM with usual care and (2) fail to specify, much less test, components of the intervention will not address the outstanding, important questions about CM. This project identified five domains and 15 specific topics for future research that would contribute to answering these questions about CM. Efforts and initiatives that focus on implementation of care delivery models, ongoing quality improvement, and supporting systems of care (e.g., the learning health care organization and frameworks for implementation) may provide perspectives that could inform future research.

There are limitations to our report. Though we attempted to engage stakeholders from a variety of perspectives, the small number of stakeholders involved makes it impossible to include the diversity of perspectives we know exist. Within stakeholder categories that were represented, there are likely to be differences in priorities and opinions that cannot be represented by one person. An additional limitation is that that our literature scan covered only the period after the CER search meaning that we did not identify studies that would have been excluded from the CER for reasons such as study design but which may address some of the specific topics prioritized by the stakeholders.

## Conclusions

Based on the finding of the CER and stakeholder input, we identified 15 specific topics for future research that fit into five domains:

- Global issues related to definitions and standardization in research
- Details related to the implementation of CM
- Optimal patient selection or targeting
- Evaluating components of complex CM interventions
- Research design considerations

Recently published studies or ongoing projects were identified that corresponded to over half of the specific topics, but this body of research is unlikely to resolve the outstanding questions about CM. Rather this list suggests a future research agenda that differs significantly from research completed to date and suggests that future studies should focus on these more specific topics identified during the course of this project rather than repeating general assessments of CM.

## References

1 Hickam DH, Weiss JW, Guise JM, et al. Outpatient Case Management for Adults with Medical Illness and Complex Care Needs. Comparative Effectiveness Review No. 99. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 13-EHC031-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.