# Acknowledgments

The Oregon Evidence-based Practice Center (EPC) would like to acknowledge the Agency for Healthcare Research and Quality Task Order Officer of this report, Christine Chang, M.D., M.P.H. We would also like to thank those who worked so conscientiously on the research team: Elaine Graham, M.L.S., Robin Paynter, M.L.S., Gabriel Valles, Dylan Waller, B.S., and Leah Williams, B.S.

The EPC sought stakeholder input on the priority areas for research. Stakeholders are not involved in the analysis or the writing of this report. Therefore, in the end, research priorities, research questions, methodological approaches, study design considerations, and/or conclusions do not necessarily represent the views of individual stakeholders.

Stakeholders must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of stakeholders who participated in developing this report follows:

## Stakeholders

- Charles Boult, M.D., M.P.H., M.B.A.
  Professor, Johns Hopkins School of Public Health
  Director, Lipitz Center for Integrated Health Care
  Baltimore, MD
- Irene Fraser, Ph.D.
  Director
  Center for Delivery, Organization and Markets
  Agency for Health Research and Quality
  Rockville, MD
- Lynda Hohmann, Ph.D., M.D., M.B.A.
  Medical Director, Office of Health Insurance Programs
  New York State Department of Health
  Albany, NY
- Chuck Kilo, M.D., M.P.H.
  Chief Medical Officer
  Oregon Health & Science University
  Portland, OR
- Elizabeth Madigan, Ph.D., R.N., FAAN
  Professor
  Frances Payne Bolton School of Nursing
  Cleveland, OH
- Deborah Peikes, Ph.D., M.P.A.
  Senior Fellow
  Mathematica Policy Research
  Princeton, NJ
- Susan Reinhard, Ph.D., FAAN, R.N.
  Senior Vice President for Public Policy, Director Public Policy Institute
  American Association of Retired Persons
  Washington, DC
- Patricia Volland, M.S.W., M.B.A.
  Senior Vice President
  Director, Social Work Leadership Institute
  New York Academy of Medicine
  New York, NY
- Nancy Whitelaw, Ph.D.
  Senior Fellow
  National Council on Aging
  Washington, DC