# Discussion

The CER concludes and stakeholders agreed that studies that (1) compare CM to usual care and (2) fail to specify, much less test, components of the intervention will not address the important questions about CM that have not been answered by existing research. This project identified five domains and 15 specific topics for future research that would contribute to answering remaining questions about CM.

The issues raised both in our assessment of prior research and our exploration of topics for future research are a reflection of the difficulties inherent in both implementing and evaluating complex, multifaceted, health services interventions. These interventions can be difficult to describe, and it can be challenging to disaggregate health services interventions into testable components. Efforts and initiatives that focus on implementation of care delivery models, ongoing quality improvement, and supporting systems of care (e.g., the learning health care organization and frameworks for implementation) may provide new perspectives that could inform future research and lead to innovative studies that help organizations provide care that will maximize the well being of people with serious illnesses and disabilities.

Our approach to identifying and prioritizing FRNs has limitations. While we attempted to engage stakeholders from a variety of perspectives, the small number of stakeholders involved makes it impossible to include the diversity of perspectives we know exist. Individuals were used to represent groups that likely include differences in priorities and opinions. In addition, limiting our literature scan to the period after that covered by the CER means that we did not identify studies that would have been excluded from the CER for reasons such as study design but which may address some of the specific topics prioritized by the stakeholders.