# Conclusion

Based on the finding of the CER and stakeholder input, we identified 15 specific topics for future research that fit into five domains:

- Global issues related to definitions and standardization in research
- Details related to the implementation of CM
- Optimal patient selection or targeting
- Evaluating components of complex CM interventions
- Research design considerations

Recently published studies or ongoing projects were identified that corresponded to over half of the specific topics, but this body of research is unlikely to resolve the outstanding questions about CM. Rather this list suggests a future research agenda that differs significantly from research completed to date and suggests that future studies should focus on these more specific topics identified during the course of this project rather than repeating general assessments of CM.