# Background

Chronic diseases affect almost half of the United States (U.S.) population and are a leading cause of illness, disability, and mortality,1 accounting for 7 out of 10 deaths among American adults.2 People with chronic diseases often require costly medical interventions and must interact with multiple health care providers. This is particularly the case when patients have more than one chronic condition or a complex condition that requires complex multiple treatments. Often the treatments and services needed are not integrated into a coherent system of care. This fragmentation increases the risk of errors, low quality care, and dissatisfaction and frustration among clinicians as well as patients and their families.3

Case management (CM) is clinical strategy that is intended to compensate for this lack of integration of health care services. The core of CM is supplemental coordination. A case manager is usually a nurse or social worker who takes responsibility for coordinating and implementing a patient's care plan, either alone or in conjunction with a team of health professionals. CM tasks include helping patients navigate health care systems, connecting them with community resources, and assisting with administrative and logistical tasks. Case managers also can perform clinical functions, including disease-oriented assessment and monitoring, medication adjustment, health education, and self-care instructions. These additional coordination or clinical functions are often part of other chronic illness management interventions such as interdisciplinary teams, integrated acute and long-term care, or home-based primary care. Because of the broad range of activities that a case manager can perform, the term CM has been used to describe a wide variety of different types of clinical program. This has led to confusion about the usefulness of CM as a clinical intervention.

In 2010, the Agency for Healthcare Research and Quality (AHRQ) charged the Oregon Evidence-based Practice Center (EPC) with conducting a review to evaluate the comparative effectiveness of outpatient CM as an intervention strategy for chronic illness management. The aims of the review were to assess the evidence pertaining to the effectiveness of CM in improving patient-centered outcomes, quality of care, and resource utilization in adults with chronic medical illness and complex care needs. It also evaluated the effectiveness of CM based on patient and intervention characteristics.

In order for the original Comparative Effectiveness Review (CER) to identify and synthesize the available evidence, the scope of the review was limited to carefully defined clinical populations and CM models.

While CM is often used to improve the management of psychiatric illnesses such as depression, schizophrenia, or substance use disorders, the content of CM services for these conditions is substantively different from the CM services provided for chronic medical illness. For this reason the review was restricted to studies about CM interventions for medical illness, as opposed to psychiatric conditions. The review did include studies in which CM was used to improve chronic medical illness care among patients who also had psychiatric illness and CM that integrated care for psychiatric disorders associated with significant medical comorbidities such as dementia. The review was further restricted to CM programs having an ongoing and sustained relationship between the case manager and patient and was limited to CM conducted in outpatient settings. Thus, it did not address short-term CM programs that focus on the transition between inpatient and outpatient settings of care.

The Key Questions the review4 addressed were:

Key Question 1. In adults with chronic medical illness and complex care needs, is case management effective in improving:

1a Patient-centered outcomes, including mortality, quality of life, disease-specific health outcomes, avoidance of nursing home placement, and patient satisfaction with care?
1b Quality of care, as indicated by disease-specific process measures, receipt of recommended health care services, adherence to therapy, missed appointments, patient self-management, and changes in health behavior?
1c Resource utilization, including overall financial cost, hospitalization rates, days in the hospital, emergency department use, and number of clinic visits (including primary care and other provider visits)?

Key Question 2. Does the effectiveness of case management differ according to patient characteristics, including but not limited to: particular medical conditions, number or type of comorbidities, patient age and socioeconomic status, social support, and/or level of formally assessed health risk?

Key Question 3. Does the effectiveness of case management differ according to intervention characteristics, including but not limited to: practice or health care system setting; case manager experience, training, or skills; case management intensity, duration, and integration with other care providers; and the specific functions performed by case managers?

The analytic framework (Figure 1) developed for the CER depicts the relationships among the Key Questions and outlines the targeted population, interventions, and outcomes that were the focus of the review.

Figure 1 Original analytic framework from Comparative Effectiveness Review

Note: Numbers refer to Key Questions.

This figure depicts the analytic framework that outlines the target population, interventions, and outcomes considered in the review. The target population includes adults with medical illness and complex care needs in outpatient settings.The intervention is case management. Patient health outcomes include overall quality of care, disease-specific quality of care, quality of life, patient satisfaction, morbidity and mortality. Resource utilization outcomes include overall cost, hospitalization rates and emergency department use. Quality of care process measure outcomes include adherence to therapy, missed appointments, patient self-management, change in health behavior, disease-specific processes of care, and physician or case manager satisfaction.

After synthesizing the results from 109 studies, the original CER concluded that, while there were a number of approaches to CM matching the review's definition and scope, the interventions had limited impact on patient-centered outcomes, quality of care, and resource utilization among patients with chronic medical illness. Nevertheless, the review was able to identify some clinical settings in which CM had positive (though modest) effects on these outcomes.

The objective of this Future Research Needs (FRN) project was to engage a range of stakeholders and combine their insight with the results of the CER and a scan of the recent literature and studies in progress. Drawing from all these sources we sought to identify and prioritize topics for future research that could inform health care decisionmaking and policy regarding CM.

## Evidence Gaps

The CER identified a number of limitations in the existing literature and research gaps. Two key limitations are described below. These are followed by important topics not found in the literature, research gaps organized according to the most relevant element of the population, intervention, comparator, outcome, timing, and setting (PICOTS) framework.

The CER also identified both limitations of existing studies and gaps in the literature. Based on these, the CER underscores how these limitations and gaps restrict the ability of the existing research literature to answer important questions about CM.

The limitations are related to a fundamental challenge the CER faced—the multiplicity of roles and the variability of day-to-day activities in different CM interventions make it difficult for evaluations of CM to specify fully the content of the intervention. This lack of specification makes it difficult to: (1) isolate components of CM that might contribute to its effectiveness and (2) be sure that indirect comparisons across studies are comparing equivalent interventions.

Past studies of CM have had methodological limitations that hinder the capability to perform comparisons of alternative models of CM. Few organizations have had the potential scope (in terms of patient base and clinical resources) to conduct evaluations that directly compare different CM approaches. Thus, nearly all research studies have compared a customized CM program to “usual care,” in which patients receive no CM services. Another limitation of the evidence base is that most of the individual clinical trials of CM have had small to moderate sample sizes (less than 500 participants per intervention arm). With these numbers it was often not possible to analyze patient subgroups, and many of the trials did not report results by subgroup. For this reason it has not been easy to determine whether CM is more effective for some subgroups of patients than for others.

## Key Research Gaps

Population | - Studies that assess the use of risk assessment tools for choosing candidates and determining which patient subgroups achieve the greatest benefits from CM.; - Better specification of populations receiving CM.
Intervention | - Studies to assess the intensity of CM including whether frequency of CM contact, length and content of contacts, and approaches to followup of problems have an effect on patient outcomes.; - Studies to determine when CM should emphasize direct support compared with patient education.; - Better specification of the components of CM interventions.
Comparator | - Studies to determine the effectiveness of CM delivered by different case managers.; - Studies to assess the potential to standardize CM and the importance of choosing individuals to implement CM.; - Studies that compare CM to other interventions designed to achieve similar outcomes.
Outcome | - None noted.
Timing | - Studies needed to determine the appropriate length of time for patients to receive CM in order to achieve the best outcomes.
Contextual Issues | - Understanding of specific areas that should be explicit in reporting the characteristic of case managers and the specifics of the CM intervention, including training received by case managers, case manager experience, specific functions of case managers and the distribution of effort devoted to different activities, modes of contact (e.g., clinic visits, home visits, and telephone calls), average caseload, relationship to other health care providers, and the use of protocols, guidelines, and information technology.

There is a relationship between the limitations of the literature and the evidence gaps. Because CM is often poorly defined and sufficient details about the patient population and the intervention are often not provided, current research evidence cannot answer questions about how to best target CM interventions. That is, which patients are most likely to benefit from specific components of CM is not clear.