# Ongoing Studies/Projects on the Effectiveness of Case Management

Investigator, Year | Objective | Study Design | Population | Completion Information | Corresponding Research Needs Domain & Topics
Bachmann-Mettler , 2011^11^ | To determine the impact of CM in cancer rehab in terms of impact on patient quality of life with an emphasis on self-management | Randomized trial | Patients with cancer | End of data collection: 12/31/2011 | D.3 Link components and outcomes
Crane12 | To use patient reported outcomes and customized case management to improve adherence and health status for patients with HIV | Randomized trial | Patients with HIV | End of data collection: 6/2013; Study completion 1/2014 | C.2 Tailoring CM based on patient characteristics
Egede, 2011 13 | To test the effectiveness of technology assisted CM for low income rural adults with type 2 diabetes | Randomized trial | Patients with type 2 diabetes | End of data collection: June 2015 | C.1 Patient targeting (exploratory analysis)
Freund, 2010^14^ | To assess clinical effects and economic implications of CM | Systematic review of randomized and non randomized trials of CM compared with routine care | Adults with at least one chronic condition in primary care | Due for completion 8/2012 per Centre for Reviews and Dissemination. No completed review located. | C.1 Patient targeting (planned subgroup analysis by chronic disease) D.3 Link components and outcomes
Freund, 2011^15^ | To determine the impact of CM conducted by Health Care Assistants in Primary care on all-cause hospitalization and quality of life | Cluster randomized trial (primary care practices will be randomized) | Primary care patients with diabetes, COPD, CHF or combination | End of data collection: 12/31/2012 | B.4 Case manager training
King's Fund, 2012^16^ | To identify how to best apply care coordination in practice | Interviews, focus groups, observations, text analyses | Primary Care patients in five sites selected as examples of effective care coordination | Due for completion late 2013 | B.1: Increase efficiency D.3 Link components and outcomes
Koopmans, 2011^17^ | To evaluate the effect of the CareWell program | Prospective cohort | Community-dwelling frail older people | End of data collection: 1/2013 | B.1: Increase efficiency D.3 Link components and outcomes
Morales-Asencio, 2010^18^ | To develop CM interventions based on patient experience and needs | 1. Interviews with patients and families; 2. Delphi with 50 clinicians/experts | Patients with COPD or heart failure | No additional information located | A.1 Definitions of CM models D.3 Link components and outcomes
National Case Management Network, 2012^19^ | To develop core competencies for case management providers | Interviews, expert consensus, discussion at annual conference | Case management across all sectors in Canada | To be completed Winter 2013 | A.1 Definitions of CM models B.4 Case manager training
Raven, 2012^20^ | To improve care and reduce health care expenditures by an intensive CM intervention. | Cluster randomized trial | High-risk, high cost fee for service Medicaid services users | End of data collection: 9/2011; Study completion 12/2012 | B.1: Increase efficiency
Versnal, 2011^21^ | To examine the effectiveness of CM in addition to a diabetes management program on quality of care | Randomization of patients already in diabetes program to either additional CM or usual care | Type 2 Diabetes and other comorbidities | Target end date: 8-31-2013 | C.2 Tailoring CM based on patient characteristics
Zwarenstein, 2011^22^ | To describe the effect of CM on patient outcomes | Systematic review Including RCTs, controlled before and after and interrupted time series | All patients as long as diagnosis is not principally one of mental illness | No information located | D.3 Link components and outcomes (for different models of CM)

Note: CM=case management; COPD=chronic obstructive pulmonary disease; RCT=randomized controlled trial.

## Appendix G References

1 Baker LC, Johnson SJ, Macaulay D, et al. Integrated telehealth and care management program for Medicare beneficiaries with chronic disease linked to savings. Health Affairs. Sep. 2011;30(9):1689-97. [pmid: 21900660].
2 Brown RS, Peikes D, Peterson G, et al. Six features of Medicare coordinated care demonstration programs that cut hospital admissions of high-risk patients. Health Affairs. June. 1. 2012. 2012;31(6):1156-66. [pmid: 22665827].
3 Hines D. Using quality improvement principles and concept analysis to refine the role of HIV case management. Care Management. 2011;17(5):7.
4 Hughes J, Reilly S, Berzins K, et al. Emergent Approaches to Care Coordination in England: Exploring the Evidence From Two National Organizations. Care Management Journals. 2011;12(4):194-201. [pmid: 23214241].
5 Peikes D, Peterson G, Brown RS, et al. How Changes In Washington University's Medicare Coordinated Care Demonstration Pilot Ultimately Achieved Savings. Health Affairs. June. 1. 2012. 2012;31(6):1216-26. [pmid: 22665833].
6 Reilly S, Abell J, Brand C, et al. Case management for people with long-term conditions: impact upon emergency admissions and associated length of stay. Primary Health Care Research & Development. Jul. 2011;12(3):223-36. [pmid: 21798120].
7 Ross S, Curry N, Goodwin N. Case management: what it is and how it can best be implemented. London. The King's Fund. 2011. www.kingsfund.org.uk/sites/files/kf/Case-Management-paper-The-Kings-Fund-Paper-November-2011.pdf.
8 Wade MJ, Desai AS, Spettell CM, et al. Telemonitoring with case management for seniors with heart failure. Am J Manag Care. Mar. 2011;17(3):e71-9. [pmid: 21504262].
9 Mayo NE, Scott S. Evaluating a complex intervention with a single outcome may not be a good idea: an example from a randomised trial of stroke case management. Age Ageing. Nov. 2011;40(6):718-24. [pmid: 22016344].
10 Rinke ML, Dietrich E, Kodeck T, et al. Operation care: a pilot case management intervention for frequent emergency medical system users. Am J Emerg Med. Feb. 2012;30(2):352-7. [pmid: 21269790].
11 Bachmann-Mettler I, Steurer-Stey C, Senn O, et al. Case management in oncology rehabilitation (CAMON): the effect of case management on the quality of life in patients with cancer after one year of ambulant rehabilitation. a study protocol for a randomized controlled clinical trial in oncology rehabilitation. Trials. 2011;12:103. [pmid: 21526985].
12 University of Washington, National Institutes of Health (NIH), National Institute of Mental Health (NIMH), National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS). Randomized Controlled Trial Using Patient Reported Outcomes and Care Managers to Improve HIV Medication Adherence in Routine Clinical Care. ClinicalTrials.gov. [Internet]. Bethesda (MD). National Library of Medicine (US). 2012. ClinicalTrials.gov/show/NCT01505660. June 14, 2012.
13 Egede LE, Strom JL, Fernandes J, et al. Effectiveness of technology-assisted case management in low income adults with type 2 diabetes (TACM-DM): study protocol for a randomized controlled trial. Trials. 2011;12:231. [pmid: 22014122].
14 Freund T, Kayling F, Miksch A, et al. Effectiveness and efficiency of primary care based case management for chronic diseases: rationale and design of a systematic review and meta-analysis of randomized and non-randomized trials [CRD32009100316]. BMC Health Services Research. 2010;10:112. [pmid: 20459654].
15 Freund T, Peters-Klimm F, Rochon J, et al. Primary care practice-based care management for chronically ill patients (PraCMan): study protocol for a cluster randomized controlled trial [ISRCTN56104508]. Trials. 2011;12:163. [pmid: 21714883].
16 The Kings Fund. Co-ordinated care for people with complex chronic conditions. The Kings Fund. 2012. www.kingsfund.org.uk/current_projects/coordinated_care/coordinated_care.html. Aug 29, 2012.
17 Radboud University, ZonMw: The Netherlands Organisation for Health Research and Development, Dutch Healthcare Authority, Health insurances CZ, Health Insurances UVIT. City of Nijmegen The CareWell-programme for Community-dwelling Frail Elderly Persons. ClinicalTrials.gov. [Internet]. Bethesda (MD). National Library of Medicine (US). 2011. ClinicalTrials.gov/show/NCT01499797. June 14, 2012.
18 Morales-Asencio JM, Martin-Santos FJ, Morilla-Herrera JC, et al. Design of a case management model for people with chronic disease (Heart Failure and COPD). Phase I: modeling and identification of the main components of the intervention through their actors: patients and professionals (DELTA-icE-PRO Study). BMC Health Services Research. 2010;10:324. [pmid: 21126369].
19 National Case Management Network (Canada). Canadian Core Competencies for Case Management Providers (Editorial Draft). National Case Management Network. 2012.
20 New York City Health and Hospitals Corporation, New York City Health and Hospitals Corporation, New York State Department of Health. A Patient Centered Intervention to Improve Health and Reduce Medicaid Costs. ClinicalTrials.gov. [Internet]. Bethesda (MD). National Library of Medicine (US). 2012. ClinicalTrials.gov/show/NCT01602848. June 14, 2012.
21 Versnel N, Welschen LMC, Baan CA, et al. The effectiveness of case management for comorbid diabetes type 2 patients; the CasCo study. Design of a randomized controlled trial. BMC Fam Prac. 2011;12:68. [pmid: 21729265].
22 Zwarenstein M, Reeves S, Straus SE, et al. Case management: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. (c. 2011). 2000;(4):CD002797.