# Recently Completed Studies/Projects on the Effectiveness of Case Management

First Author, Year | Objective | Study Design | Population | Intervention | Results | Corresponding Research Needs Domain and Topics
Baker, 2011^1^ | To evaluate the impact of CM integrated with a telehealth tool on costs | Controls: usual care matched to CM patients, pre-post design | High cost Medicare beneficiaries | CM and a telehealth tool | Savings of approximately 7.7 to 13.3% | B.1: Increase efficiency D.3 Evaluation of CM components
Brown, 2012^2^ | To identify program elements in CM that reduce hospitalizations | Subgroup analysis of Medicare Demonstration project | Patients at high risk of hospitalization | CM associated with reduction of hospitalizations | Identified six elements of CM programs that reduced hospitalizations. | B.3 Implementations: Modes of communication D.1 Medications management D.2 Transition care
Hines, 2011^3^ | To examine and redefine the roles of HIV case managers to improve care | Case studies and surveys | People with HIV served by state programs | CM for people with HIV | CM activities and functions were delineated and participants developed a revised model of coordination among state and local programs. | B.1 Increase efficiency B.4 Case manager training
Hughes, 2011^4^ | To identify similarities and differences in the services in goals, function and tasks of two programs. | Policy analysis and surveys | Organizations (local authorities and primary care trusts in the UK) | Care management and case management as implemented in UK | Both were designed to shift care from high cost services to home. They differ in terms of more specific goals, the people they serve, and the staff used. | A.1 Definitions of models
Peikes, 2012^5^ | To determine the effectiveness of a redesigned CM program | RCT with a redesigned CM intervention | Medicare beneficiaries in demonstration project | Redesign included local care managers, stronger transitional care and medication management, more in-person contact, and more thorough assessments. | Hospitalizations were decreased without increasing spending. Spending was reduced 9.7% in the higher risk group. Use of CM assistants for lower risk patients contributed to financial sustainability. | B.1 Increase efficiency B.3 Modes of communication B 4 Case manager training D.1 Medication management D.2 Transition care D.3 Link components and outcomes
Reilly, 2011^6^ | To evaluate the implementation and impact of case management | Survey of practice manager sand retrospective cohort analysis of patient records | Primary care patients with long-term conditions | CM as delivered in 10 primary care practices | Detailed description of CM in the 10 sites, including similarities and differences across sites. Features of CM had only a modest effect on effectiveness. | A.1 Definitions of CM models C.1 Patient targeting D.3 Link components and outcomes
Ross, 2011^7^ | To examine how case management can be implemented successfully | Literature review and case studies | Programs that have successfully implemented case management | Long term case management programs, mostly in primary care | Identified core components of case management and factors associated with successful case management. | A.1 Definitions of CM models B.2 Integration B.4 Case manager training D. 3 Link components and outcomes
Wade, 2011^8^ | Assess nurse case management with telemonitoring | RCT | Elderly patients with heart failure | Telemonitoring added to CM | No difference in clinical outcomes or quality of life—no incremental benefit. | D.3 Link components and outcomes
Mayo, 2011^9^ | To determine impact of CM on any patient outcomes, allowing diversity of outcomes across patients. | Reanalysis of RCT | Stroke patients | Nurse case management | Patients in CM were more likely (OR 1.41) to have one or more positive outcome. Comparisons on each outcome found no significant difference. | None
Rinke, 2012^10^ | To pilot test CM for frequent users of Emergency Medical Services | Pre-post (n=10) | Frequent EMS users | Case manager with nurse liaison backup | Transport responses and costs decreased compared to predictions based on prior use. | None

Note: CM=case management; EMS=emergency medical services; HIV=human immunodeficiency virus; RCT=randomized controlled trial.