# Responses to Open-Ended Question: What Aspects of Case Management Should Be Measured and Reported?

| Stakeholder Responses | Topic Code
1 | Whether [the intervention] was implemented as designed | Implementation
2 | Intensity/duration | Implementation
3 | Duration | Implementation
4 | Termination criteria | Implementation
5 | Type and frequency of interactions between patient/family and CM and where relevant other members of the team. | Implementation
6 | The frequency with which the contacts are made | Implementation
7 | Mode of contact (phone vs. in-person) | Implementation
8 | How the contact is made and what is done at each contact. e.g. two in-person visits for assessment and motivational interviewing with 5 intervening phone calls for coaching and patient education. | Implementation
9 | Access to data | Implementation
10 | Might actually do very specific observational studies examining the specifics of how case managers function, integrate, manage data, etc. | implementation
11 | What the intervention was | CM description/components
12 | Approach to education | CM description/component
13 | How medication management is done | CM description/component
14 | Care plan details (what is covered, what is shared w/patients, usual care providers, and care manager) | CM description/component
15 | Greater specificity of all aspects of the interventions | CM description/component
16 | Detail of the interventions provided | CM description/component
17 | Medication management (not just adherence) | CM description/components
18 | Family caregiver interventions | CM description/components
19 | In-patient intervention | CM description/components
20 | Program components | CM description/components
21 | What happens after [24 hrs]--care versus care coordination | CM description/components
22 | Interaction with usual care providers | Environment/context
23 | Site/context | Environment/context
24 | Implementation process/challenges | Environment/context
25 | Type and frequency of interactions between and among team members with primary care provider | Environment/context
26 | How CM fits into the overall design of the clinic | Environment/context
27 | Clinic design into which CM fits best | Environment/context
28 | Leadership and culture issues critical to CM success | Environment/context
29 | The cost outcome | Cost
30 | All program costs | Cost
31 | ROI | Cost
32 | Long term projection of cost changes (regression to mean?) | Cost
33 | Original characteristics of the patient | Patient selection/characteristics
34 | Patient selection criteria | Patient selection/characteristics
35 | Selection criteria for CM | Patient selection/characteristics
36 | Identification of population targeted for CM | Patient selection/characteristics
37 | Goals | Outcomes: general
38 | Effects on all stakeholders | Outcomes: general
39 | Major system impact of CM (i.e., hospitalizations, medication compliance) | Outcomes: general
40 | The clinical outcome | Clinical outcomes
41 | Quality measures including patient/family satisfaction, impact of interventions on patient/family^a^ | Clinical outcomes
42 | Background/training of CMs | Case manager characteristics
43 | Effective care manager requirements | Case manager characteristics
44 | Identification of all members of the team and roles/responsibilities | Case manager characteristics
45 | Caseload | Caseload
46 | Case loads | Caseload
47 | Quality measures including patient/family satisfaction, impact of interventions on patient/family^a^ | Patient satisfaction
48 | Patient satisfaction as an outcome | Patient satisfaction
49 | The manner in which multicultural issues are addressed | Multicultural
50 | CM as a continuous improvement method | Other
51 | What happens in 24 hours | Not coded
52 | Proportion incoming vs. outgoing contacts | Not coded

a Multiple codes applied to this response