# Detailed Topic Rankings Ordered by Mean Score^a^

Rank | Topic | Mean Score | High Priority: Ranked 5-6 % (n) | Medium Priority: Ranked 3-4 % (n) | Low Priority: Ranked 1-2 % (n)
1 | Studies that establish clear definitions of specific models of CM based, for example, on their components, intensity and duration. | 5.67 | 100% (9) | 0% (0) | 0% (0)
2 | Studies that establish pragmatic standards for measuring and reporting CM characteristics and outcomes that should be routinely reported in journal articles/study protocols about CM. | 5.22 | 78% (7) | 22% (2) | 0% (0)
3 | Studies of how CM can be made more efficient so that it is either cost neutral or generates savings. | 5.11 | 78% (7) | 11% (1) | 11% (1)
4 | Studies with pragmatic standards for measuring and reporting relevant outcomes, such as utilization, all stakeholders' costs, quality of care, quality of life, and satisfaction. | 5.11 | 67% (6) | 33% (3) | 0% (0)
5 | Studies that compare CM programs that include access to utilization data and the ability to follow patients across settings and episodes with CM that is limited to specific settings or time periods. | 5 | 78% (7) | 11% (1) | 11% (1)
6 | Studies that describe the characteristics of patients in case management (CM) programs that result in positive outcomes (benefits for patients or positive changes in utilization). | 4.89 | 78% (7) | 11% (1) | 11% (1)
7 | Studies that describe longitudinal evaluation of the impact of CM, particularly for those with chronic illnesses and near the end of life. | 4.89 | 78% (7) | 11% (1) | 11% (1)
8 | Studies that examine the role of evaluating the appropriateness of prescribed medications (using existing medication evaluation tools or involving a pharmacist) as part of CM (not simply evaluating adherence). | 4.78 | 67% (6) | 33% (3) | 0% (0)
9 | Studies that examine the role of including transitional care tools or models as part of CM. | 4.78 | 56% (5) | 44% (4) | 0% (0)
10 | Studies to determine the modes of case manager contact (e.g., telehealth, telephone, in-person, home visits, in physician's office, etc.) that are most effective. | 4.78 | 67% (6) | 22% (2) | 11% (1)
11 | Exposition of the pros and cons of various study designs that would be most productive at this stage (e.g., randomized, cluster-randomized, observational, community trials, qualitative). | 4.78 | 67% (6) | 33% (3) | 0% (0)
12 | Studies that examine the impact of tailoring CM activities based on patient characteristics.^b^ | 4.75 | 75% (6) | 0% (0) | 25% (2)
13 | Studies that determine the effectiveness of aligning CM onset, intensity, composition and duration with the patient's needs. | 4.67 | 67% (6) | 22% (2) | 11% (1)
14 | Studies that compare the impact of differences in training/education of case managers. | 4.56 | 56% (5) | 33% (3) | 11% (1)
15 | Studies that examine the link between specific components of case management and specific outcomes (e.g., coordination of care and hospitalization; patient coaching and adherence). | 4.56 | 56% (5) | 33% (3) | 11% (1)
16 | Studies that assess the use of risk assessment tools for choosing patients most likely to benefit from CM. | 4.44 | 44% (4) | 56% (5) | 0% (0)
17 | Studies of CM for patients with multiple comorbidities and issues (i.e., studies that do not exclude patients based on severity, diagnosis, or other aspects of need). | 4.44 | 67% (6) | 22% (2) | 11% (1)
18 | Studies that compare the effectiveness of standardized CM protocols with more flexible CM protocols. | 4.44 | 56% (5) | 44% (4) | 0% (0)
19 | Studies of how CM can be incorporated into Accountable Care Organizations. | 4.44 | 56% (5) | 33% (3) | 11% (1)
20 | Studies that examine the effects of different payment approaches (e.g., capitation vs. shared savings vs. fee for service). | 4.44 | 56% (5) | 22% (2) | 22% (2)
21 | Studies with large sample sizes (more power) – e.g., large observational cohort studies, large trials and/or registries. | 4.33 | 44% (4) | 44% (4) | 11% (1)
22 | Studies of alternative CM models or new models of care that include CM. | 4.33 | 56% (5) | 33% (3) | 11% (1)
23 | Studies that evaluate how long patients should be enrolled in CM and what should trigger disenrollment. | 4.33 | 56% (5) | 33% (3) | 11% (1)
24 | Studies that examine the role of comprehensive medical management in CM (e.g., ability of case manager to make clinical recommendations or decisions, such as adjusting medications or treatments). | 4.22 | 56% (5) | 22% (2) | 22% (2)
25 | Studies that examine whether timing of CM after hospital discharge is associated with effectiveness of CM. | 4.22 | 44% (4) | 33% (3) | 22% (2)
26 | Studies that examine different settings and organizations for case management (e.g., role of a single person versus part of primary care). | 4.22 | 56% (5) | 33% (3) | 11% (1)
27 | Studies of whether the known risk factors for rehospitalization (e.g., functional status, social support, number of past hospitalizations) would be useful in targeting CM.^b^ | 4.13 | 50% (4) | 25% (2) | 25% (2)
28 | Studies that compare case managers integrated into teams versus case managers working alone. | 4.11 | 67% (6) | 11% (1) | 22% (2)
29 | Studies that examine the relationship of the case manager with the patients and families and how that relationship impacts outcomes. | 4.11 | 44% (4) | 44% (4) | 11% (1)
30 | Studies to assess whether CM protocols are followed (e.g., fidelity assessments to document whether CM is actually implemented as planned). | 4.11 | 56% (5) | 33% (3) | 11% (1)
31 | Studies of the impact of patient-provider interaction techniques or models (e.g., motivational interviewing, coaching, or stages of change) on the effectiveness of CM. | 4.11 | 44% (4) | 33% (3) | 22% (2)
32 | Studies that compare CM programs that vary in intensity. | 4.11 | 56% (5) | 22% (2) | 22% (2)
33 | Studies that establish the core components/minimum elements needed for CM. | 4.11 | 56% (5) | 11% (1) | 33% (3)
34 | Studies that determine the effectiveness of different forms of all of the components of CM (including assessment, evidence-based care planning, patient/family education, engagement/coaching for self-management, coordination of care, proactive monitoring, integrating with community agencies). | 4.11 | 56% (5) | 22% (2) | 22% (2)
35 | Studies that compare the effectiveness of different CM components rather than compare CM with usual care. | 4.11 | 56% (5) | 22% (2) | 22% (2)
36 | Studies to assess effects of CM in high health services utilization versus low-utilization geographic regions. | 4 | 33% (3) | 56% (5) | 11% (1)
37 | Studies to assess the impact of patient activation (a specific measure that includes confidence, engagement, skills and knowledge) on the effectiveness of CM. | 3.89 | 44% (4) | 33% (3) | 22% (2)
38 | Studies that determine what strategies are most effective to engage persons in CM who are otherwise disengaged from the health care system. | 3.89 | 44% (4) | 33% (3) | 22% (2)
39 | Studies that compare the impact of case managers from different disciplines (e.g., nurses, social workers, pharmacists). | 3.89 | 33% (3) | 44% (4) | 22% (2)
40 | Studies that compare the effectiveness of CM focused on patient education with CM focused on direct patient support activities (e.g., coaching, coordinating care). | 3.89 | 44% (4) | 22% (2) | 33% (3)
41 | Studies of the impact of CM on families of patients and whether that impact is related to other outcomes. | 3.89 | 44% (4) | 22% (2) | 33% (3)
42 | Studies that examine the influence of family caregivers on CM outcomes. | 3.89 | 22% (2) | 67% (6) | 11% (1)
43 | Studies of other outcomes of CM, such as whether or not it reduces pressure on other parts of the system (i.e., does it make physician's work easier?). | 3.89 | 22% (2) | 78% (7) | 0% (0)
44 | Studies that compare the effectiveness of CM based in different types of organizations (e.g., insurer, non-profit, hospital-based, primary care provider based, specialist provider based). | 3.89 | 44% (4) | 44% (4) | 11% (1)
45 | Studies that compare CM in integrated systems with CM in organizations that are not part of an integrated system. | 3.89 | 44% (4) | 33% (3) | 22% (2)
46 | Studies that examine the role of primary care providers in identifying patients who could benefit from CM. | 3.67 | 22% (2) | 56% (5) | 22% (2)
47 | Studies that assess how to keep case managers focused on the highest-impact components of CM (e.g., supervision and/or incentives). | 3.67 | 22% (2) | 44% (4) | 33% (3)
48 | Studies that establish criteria for rating the quality of CM programs (so that quality of CM programs and the effectiveness of programs at different levels of quality can be compared). | 3.67 | 44% (4) | 11% (1) | 44% (4)
49 | Studies in which resource utilization is the primary outcome for CM. | 3.67 | 22% (2) | 56% (5) | 22% (2)
50 | Studies to evaluate what is the right caseload for case managers. | 3.56 | 44% (4) | 22% (2) | 33% (3)
51 | Studies to assess the impact of the use of information technology on the effectiveness of CM. | 3.56 | 22% (2) | 67% (6) | 11% (1)
52 | Studies to determine the impact of patient literacy (or the case manager's ability to address patient literacy) on effectiveness of CM. | 3.44 | 22% (2) | 56% (5) | 22% (2)
53 | Studies to assess the impact of patient motivation (e.g., reason for enrollment, personal efficacy). | 3.44 | 22% (2) | 56% (5) | 22% (2)
54 | Studies of the impact/importance of the characteristics of the individual serving in the role of case manager (individual traits such as personality, motivation, etc.). | 3.44 | 44% (4) | 11% (1) | 44% (4)
55 | Studies that compare CM with other non-CM interventions designed to achieve similar outcomes. | 3.44 | 33% (3) | 33% (3) | 33% (3)
56 | Studies that compare CM programs that automatically enroll patients with programs where patients have to choose to enroll (i.e., opt-in vs. opt-out programs). | 3.33 | 22% (2) | 44% (4) | 33% (3)
57 | Studies to assess potential ways to standardize CM. | 3.22 | 33% (3) | 22% (2) | 44% (4)
58 | Studies that compare CM programs with different specific missions or focuses (e.g., focus on preventing major events like hospitalization versus supporting behavior change). | 3.22 | 22% (2) | 33% (3) | 44% (4)
59 | Studies of CM in managed care/health plans/non-academic settings. | 3.22 | 22% (2) | 33% (3) | 44% (4)
60 | Studies that compare different ways to provide patient education within CM. | 3 | 11% (1) | 56% (5) | 33% (3)
61 | Studies that compare characteristics of patients who choose to participate with those who choose not to participate in CM. | 2.67 | 0% (0) | 44% (4) | 56% (5)

a Mean score is out of a possible 6. Some percentages do not equal 100 due to rounding.

b n=8 for these two topics due to a stakeholder skipping them on the questionnaire.

Note: CM=case management