# Detailed Search Strategy for Recent and Ongoing Studies

OvidSP MEDLINE(R) and OvidSP OLDMEDLINE(R) 1946 to June Week 1 2012, OvidSP MEDLINE(R) In-Process & Other Non-Indexed Citations

June 13, 2012

Date searched: 06/13/2012

1 | exp Patient Care Planning/ | 48333
2 | ((manag$ or oversee$ or supervis$ or coordin$) adj5 ((patient$ adj3 care) or (case or cases))).mp. | 37989
3 | 1 and 2 | 8845
4 | limit 3 to english language | 8335
5 | limit 4 to “all adult (19 plus years)” | 2590
6 | limit 4 to “all child (0 to 18 years)” | 1284
7 | 5 or 6 | 3323
8 | 4 not 7 | 5012
9 | 8 or 5 | 7602
10 | 9 and (201108* or 201109* or 201110* or 201111* or 201112* or 2012*).ed. | 287

CINAHL Plus with Full Text (1937-Wednesday, June 13, 2012)

Date searched: 06/13/2012

S5 | S3 and S4 | Search modes - Boolean/Phrase | 400
S4 | ((manag* or oversee* or supervis* or coordin*) N5 ((patient* N3 care) or (case or cases))) | Search modes - Boolean/Phrase | 21561
S3 | S1 or S2 | Limiters - English Language; Exclude MEDLINE records; Published Date from: 20110801-20121231 Search modes - Boolean/Phrase | 400
S2 | MH “Case Managers” | Search modes - Boolean/Phrase | 2102
S1 | MH “Case Management” | Search modes - Boolean/Phrase | 11159

OvidSP EBM Reviews - Cochrane Central Register of Controlled Trials June 2012

Date searched: 06/13/2012

1 | case manag$.ti,hw,kw. | 646
2 | limit 1 to yr=“2011 -Current” | 30

OvidSP EBM Reviews - Cochrane Database of Systematic Reviews 2005 to May 2012

Date searched: 06/13/2012

1 | case manag$.ti,kw. | 9
2 | case manag$.oh,tw. | 134
3 | 1 or 2 | 134
4 | limit 3 to last year | 31

OvidSP EBM Reviews - Database of Abstracts of Reviews of Effects 2nd Quarter 2012

Date searched: 06/13/2012

1 | case manag$.ti,kw,tw. | 104
2 | limit 1 to last year | 104

ClinicalTrials.gov

Date searched: 06/13/2012

“case management” OR “case manager” OR “nurse case manager” OR “care managers” OR “nurse case manager” \| Adult, Senior \| received from 08/15/2011 to 06/14/2012 \| updated from 08/15/2011 to 06/14/2012

Current Controlled Trials

Date searched: 06/14/2012

Case management OR case manager

International Clinical Trials Registry Platform Search Portal (ICTRP)

Date searched: 06/14/2012

Title: case management OR case manager Also searched: Intervention: case management OR case manager Date of registration: 18/08/2011 and 14/06/2012

Scopus (1960-present)

Date searched: 06/14/2012

TITLE ABS KEY(case PRE/1 manage*) AND DOCTYPE(cp) AND SUBJAREA(mult OR medi OR nurs OR vete OR dent OR heal OR mult OR arts OR busi OR deci OR econ OR psyc OR soci) AND PUBYEAR > 2010

NIH Research Portfolio Online Reporting Tools (NIHRePORTER)

Date searched: 06/14/2012

Text Search (Logic): “case management” OR “case manager” Award Notice Date > 08/15/2011

Health Services Research Project in Progress (HSRProj)

Date searched: 06/14/2012

(“case management” OR “case manager”) Project status = Ongoing : Initial Year Range = 2011 - 2012

Agency for Healthcare Research and Quality Grants On-Line Database (AHRQ Gold)

Date searched: 06/14/2012

All 3 searches: AHRQ Research Grants database \| HHS Recovery Act Projects \| AHRQ Working Papers: abstract text\|project description text\|abstract/research text: “case management” OR “case manager”

Foundation Center Directory Online

Date searched: 06/14/2012

Keyword search: “case management” OR “case manager” Year Authorized: From 2011 to 2012 Subjects: health care, health organizations, heart & circulatory diseases, heart & circulatory research, medical care, outpatient services; medical care, rehabilitation; medical care, community health systems; medical research; cancer; diabetes; nursing care; public health; research; senior continuing care; substance abuse prevention; substance abuse, services; terminal illness, people with; Also searched Types of Support: research