# Online Questionnaire

The following thirteen pages show images of the online questionnaire stakeholders used to prioritize the evidence gaps for case management in adults with complex care needs. The questionnaire was created using the web-based survey program SurveyMonkey. The questionnaire consists of three sections. The first section provides instructions and asks stakeholders to identify their perspective (as a clinician/researcher, research funder, policymaker, payer, consumer advocate, or other). It also solicits some basic information about the respondent such as name and organization. The second part of the questionnaire consists of 61 areas identified as research gaps through the original comparative effectiveness review and through stakeholder engagement. These 61 areas are grouped together loosely based on the corresponding PICOTS (Population, Intervention, Comparator, Outcome, Timing, and Setting) they address as well as an other category for those items that do not fit into a specific category. Each question has a 6-point scale with 1 indicating that the topic is of the lowest priority and 6 being the highest priority for future research. The final section consists of four open-ended questions about how future research should be different than current research, what key items should be measured or reported in all future case management studies, what elements should make up a standardized definition of case management, and whether the stakeholder knows of any ongoing or recently completed studies. Following these questions, there is also a space for stakeholders to provide any additional comments they may have had.