# Stakeholder Invitation

[Stakeholder Name]

[Organization]

[Address]

[Date]

Dear [Stakeholder],

The Oregon Evidence-based Practice Center (EPC) was commissioned by the Agency for Healthcare Research and Quality (AHRQ) to prioritize future research needs in the area of Outpatient Case Management for Adults with Medical Illness and Complex Care Needs. We are interested in identifying case management topics that are important to stakeholders so that future research can address the most pressing needs and better inform clinical decision-making and health policy. You have been nominated as a stakeholder with an interest in this area, and we would like to invite you to help us in this effort. Your participation would involve:

1. One 90-minute webinar. This will be offered on two dates. The first webinar will be held on Thursday, May 31^st^ from 11:00 am-12:30 pm Pacific Time (2:00 pm-3:30 pm Eastern Time). The second webinar will be held on Monday, June 11^th^ from 10:00 am-11:30 am Pacific Time (1:00 pm-2:30 pm Eastern Time). You only need to be present during one of the sessions, and if you cannot make it to either, we may be able to arrange a telephone interview at another time. During the webinar, we will present the findings from the recently completed EPC evidence review, including information gaps that were identified and will facilitate a dialogue among participants to generate additional topics for inclusion in prioritizing future research. The goal of the webinar is to create a list of evidence gaps that will then be prioritized by yourself and other stakeholders.
2. 1-2 rounds of prioritizing identified topics using a web-based questionnaire. Participants will then take part in a modified Delphi process to prioritize research topics. They will receive a link to a prioritizing questionnaire (and instructions) after the webinar. The questionnaire will take approximately 15-30 minutes to complete and will be ready approximately two weeks after the second webinar session. If a second round of ranking is required, it will take about 5-10 minutes of your time.

We hope you will be able to contribute your perspective and expertise in this effort to inform future research, decision-making, and policies regarding outpatient case management for adults with complex care needs.

Please confirm whether or not you will be able to participate in this project by [One week from when sent]. When confirming please indicate which webinar session you would like to attend or if you need to make other arrangements. Upon agreement to participate, you will be requested to complete an EPC conflict of interest disclosure form. We will send background materials to stakeholders prior to the webinar sessions

If you have any questions, or would like additional information, please contact Annette Totten at totten@ohsu.edu or Jesse Wagner at wagnerje@ohsu.edu or (503) 494-4592.

Sincerely,