# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
CM: Case Management
EHC: Effective Health Care Program
EPC: Evidence-based Practice Center
FRN: Future Research Needs
IRB: Institutional Review Board
NCMN: National Case Management Network
NYU: New York University
PICOTS: Populations, interventions, comparators, outcomes, timing, and setting
U.S.: United States
WHO: World Health Organization