# Results

## Prioritization of Research

Interim results, from the two prioritization exercises, are presented in Appendix H. Only research gaps prioritized by the stakeholders two or more times (n=13) were included in the final list. The following is the final prioritized list of potential research studies. We present PICOTS and a summary of study design considerations here; detailed rationales can be found in Appendix A. Although the research priorities are listed from 1 to 13, numbers 1, 2, and 3 had identical levels of enthusiasm from the stakeholders.

### Research Need #1 What are effective methods of integrating primary care into specialty mental health practice settings? Studies would include both mental and general health outcome(s) (e.g., obesity and depression)

Population. Adults with serious mental illness. This may include people with psychotic disorders such as schizophrenia, major depressive disorder, bipolar disorder, and serious anxiety disorders.

Intervention. Delivery of primary medical care in the mental health setting, which could include on-site services by a physician’s assistant, nurse practitioner, or primary care physician, or a systematic collaborative effort such as case identification through screening, treatment plans developed jointly between providers, and joint decisionmaking in defined roles. An alternative intervention would be provision of some services through health IT, such as telemedicine interventions.

Comparator. Usual care, with referral of patients to primary care providers in the local medical community, including referrals to local community health centers.

Outcome. Process measures of care including proportion of patients who receive appropriate preventive interventions such as hypertension screening, colorectal cancer screening, lipid screening, and women’s health screening. Additional measures include dietary counseling and diabetes screening for people with obesity. Chronic disease process measures include diabetes care management among those with adult onset diabetes mellitus. Process measures should also include evidence of care coordination and specialty referral when appropriate. Patient-centered outcomes could include control of blood pressure in those who have identified hypertension and control of hyperlipidemia among those with severely elevated lipids or diabetes. Health care utilization outcomes include measures such as emergency department visits. Health care quality of life would of course be the most patient-centered outcome and would measure outcomes of both mental health and general medical care. Patient and mental health clinic satisfaction would be secondary outcomes.

Timeframe. To evaluate success, a minimum of 1 year of intervention time would be required.

Setting. Mental health practices with large numbers of patients with serious mental illness, and with sufficient numbers of patients to justify such on-site care.

Study Design Considerations. We could envision several study designs to enhance understanding of integration of primary care into mental health.

- Demonstration pilots may well be needed to determine the acceptability and feasibility of this type of integrated care.
- Use of claims data with propensity matched controls and difference-in-difference models are a relatively low-cost approach to assessing patient-level outcomes.
- Prospective observational studies with control for clinic and patient characteristics are another option, although with the expected challenges of the need to control for case mix and practice environmental differences between settings.
- Randomized trials of integration of primary care into specialty mental health practice will require randomization at the level of the practice, with analysis using clustered methods. Randomization at the level of the individual would likely be administratively infeasible. The primary unit of analysis in such studies would be at the level of the patient. Sample size would depend on the size of any practice effects, because patients are clustered within practices. Sample size would also depend on the outcome measure used.

### Research Need #2 Effectiveness of cross-cutting models/strategies for integration of mental health into primary care

Note: “Cross-cutting” here indicates care across multiple mental health diagnostic categories (e.g., depression or anxiety disorder), as opposed to a separate strategy for each diagnostic category.

Population. Individuals with mental health diagnoses such as anxiety disorder, somatization disorder, problem drinking, or depression, seen in primary care settings using integrated care.

Intervention. An integrated approach to mental health care delivery. The same personnel would address multiple mental health diagnoses. The diagnostic and treatment protocols would be specific to each diagnosis, but the systems of screening, case identification, followup, and communication among the members of the care team would be similar across the mental health diagnoses.

Comparator.

A. Feasibility and fidelity studies would not require a comparison group.
B. Tests of the efficacy of the cross-cutting approach could be conducted with two potential comparison conditions:
  – Use of different personnel for each mental health diagnosis, for example, a separate program, with separate personnel for each diagnosis (depression, problem drinking). This could be called “diagnosis-specific care,” which may not emulate actual practice. Specifically trained non-MD/PhD personnel may have specialized expertise, although the efficiency of the care integration may be an issue.
  – Care as usual, without integration.

Outcomes. An initial outcome would be the feasibility of such cross-cutting care. Is it acceptable to the mental health and primary care providers? If the intervention is feasible, next steps would be assessment of process measures of quality of care. For tests of efficacy, outcomes would include condition-specific clinical outcomes similar to those considered for other integrated care intervention studies. An additional outcome would be an assessment of the costs of cross-cutting integrated care compared to diagnosis-specific care. Costs might be lower when the same personnel are used across diagnoses. Provider and patient satisfaction could also be assessed.

Timeframe. Practices would need at least 1 year in order to assess such a cross-cutting care system. For some research questions, such as the feasibility of the cross-cutting care, no run-in period would be appropriate, since the study is intended to evaluate such implementation issues. Studies of cost, however, would be more appropriate after the care systems are established and shown to be effective.

Setting. Primary care clinics implementing mental health integration practices.

Study Design Considerations.

- Studies of the feasibility and fidelity of cross-cutting integrated care will be case studies. Are integrated care principles in a cross-cutting framework acceptable and feasible for practices, providers, and patients? Testing in several primary care settings would be needed, including large practices such as the VA or closed-panel health maintenance organizations, public settings such as community health centers, and private practices.
- Once feasibility is established, studies of the efficacy of the cross-cutting approach can employ randomized trials, with the practice site as the unit of randomization. Depending on the comparator used (usual care vs. diagnosis-specific care), the required sample size would be either moderate or very large (see section on power analysis below).

### Research Need #3 Studies examining the use of information technology (IT) including text messaging, use of the Internet, and effective use of electronic health records for integrated mental and general medical health care

Note. These would focus on true interoperability and sharing of information between the primary care and the mental health professionals.

Population. Individuals with mental health diagnoses seen in primary care settings using integrated care.

Intervention. Use of IT to deliver mental health care to patients seen in primary care settings. Mental health providers would need to be involved in the delivery of care. Sharing of queries among providers and movement of text-based data by the mental health provider into the primary care electronic health record will be an important component of “meaningful use.”

Comparator. Integrated care that does not utilize electronic IT.

Outcome. Both process and patient-centered measures could be used. Process measures would include the number of patients treated through the intervention per mental health professional, the quality of care provided using standard metrics, the costs of the intervention, and the satisfaction of providers and staff with the IT intervention. Outcome measures would include the proportion of patients who respond to treatment and the satisfaction of patients with the IT intervention. The precise metrics used would depend on the mental health diagnoses addressed.

Timeframe. IT interventions have a substantial learning curve. A minimum of 6 months is generally used prior to examination of the effect of an IT intervention. The duration of the observation should be at least 1 year.

Setting. Primary care clinics wishing to utilize integrated care for mental health problems.

Study Design Considerations. We could envision several study designs to enhance understanding of the use of information technology in the integration of mental health into primary care.

- Demonstration projects at a limited number of sites could be used to assess the feasibility of such interventions.
- Randomized trials or observational studies with a contemporaneous control group. The practice would need to be the unit of randomization. Randomizing patients within a practice would likely not be possible due to administrative complexity and possible contamination of the control patients.
- If the comparison arm is integrated care without health IT components, the effect on outcomes would likely be modest. This would necessitate a very large sample size on the order of 12,000 patients (see power analysis below).

### Research Need #4 Studies examining the sustainability of integrated care without external support such as grant funding. Integrated care can be delivered with special grant funding but are there ways of supporting it following or in lieu of grant funding?

Population. The unit of intervention and analysis is the integrated care organization, not the patient or the provider. The populations cared for could be either adults or children and the clinics either primary care or specialty mental health in public or private settings.

Intervention. Integrated care, either in primary care or mental health settings. It is important that the specifics of the integrated care system be described in order to assess applicability to the user community. The systems of interest would be those that had been able to successfully deliver services for at least 1 year without external grant support. Cost-sharing across settings would be important to document.

Comparator. Integrated care systems that after a period of time do not make the transition to sustainability either by continuing to require grant subsidies or by ceasing integrated care operations.

Outcome. Successful functioning of the integrated care system. Identification of the organizational characteristics of health care systems and integrated care organizations that successfully deliver services without funding external to the health care system. Specific outcomes might include the percentage of patients continuing to receive integrated care at 1, 3, and 5 years after funding has ceased; the number of co-located specialists at 1, 3, and 5 years; and patient and provider satisfaction at 1, 3, and 5 years.

Timeframe. At least 1 year, but longer-term sustainability will necessitate following practices and programs through several budget cycles, up to 5 years.

Setting. Public or private settings.

Study Design Considerations. Case studies of both successes and failures to sustain integrated care.

- Both qualitative and quantitative information could be used. Qualitative information might include interviews with practitioners, administrators, and payers. What led them to continue with the program after the end of the initial grant or contract? Which components were sustained and why? Quantitative information needed includes the financial aspects of the grant that the integrated care system started with, as well as documentation of any internal transfers that are occurring after the end of the grant. Such transfers sometimes occur through use of health care organization quality improvement funds.
- If data were available, larger secondary analyses could be conducted of integrated care systems. An example might be examination of VA systems or state mental health systems if they had sufficient variability across practices.

### Research Need #5 Studies examining the dissemination of successful models/strategies into community settings. How can efficacious interventions be incorporated into everyday practice in the face of weak incentives and competing medical priorities?

Population. The unit of analysis is the integrated care practice, not the patient or the provider. The populations cared for could be either adults or children and the clinics either primary care or specialty mental health, in either public or private settings.

Intervention. Implementation of integrated care in community settings. The level of integrated care and incentives used to motivate clinicians will need to be documented using a standardized format such as that outlined in Appendix H as derived from the 2008 AHRQ report.

Comparator. Any efficacy study including implementation of integrated care in the larger settings of VA facilities and academic practices where most of the published studies have been based. The comparator does not necessarily need to be contemporaneous.

Outcome. Fidelity of the intervention to integrated care as developed and implemented in published studies.

Timeframe. Implementation for at least 1 year to determine if it is sustainable.

Setting. The practices would be community settings such as VA or federally qualified health centers (FQHCs) and private practices that have adopted integrated care.

Study Design Considerations.

- One approach would be to re-conduct randomized trials of integrated care in community settings including smaller practices, private practices, and rural practices. Such study replication would be expensive, and integrated care has already been demonstrated to be effective in multiple trials. Examination of fidelity of implementation in community practices would be substantially less expensive.
- Studies examining the fidelity of the integrated care intervention would be qualitative and organizational.
- Given that relatively little research has been conducted to date on integration of primary care into specialty mental health practice, studies examining the generalizability of those models may be premature pending additional efficacy studies.
- Since the studies are largely qualitative and organizational, the main focus will be on lessons learned from implementation in community settings. What are the common adaptations necessary for successfully implementing integration practices in the community setting? Sample sizes will not need to be large, but different types of interventions will need to be examined: private practices as well as VA/FQHCs, rural as well as urban, etc. Several case studies will be needed for each type of practice. Given the variety of settings and populations, at least 8–12 practices will need to be examined. Small or rural practices may need to adapt integrated care interventions to their circumstances, and documentation regarding how interventions change will be useful to the practitioner community.

### Research Need #6 Studies examining effective models/strategies of integrated or “bundled” payment for integrated care. Are there effective ways of combining primary care reimbursement mechanisms with reimbursements for mental health care services?

Population. The main unit of intervention would be the organization delivering the integrated care. These could be either mental health services delivered in primary care settings or primary care services delivered in mental health settings. Specialty services such as outpatient cardiology or orthopedic surgery would presumably be excluded.

Intervention. Bundled payment for services across mental health and primary care. This may or may not include hospital services.

Comparator. Similar organizations using fee-for-service reimbursement. As noted in the 2008 AHRQ review,2 there is substantial variability in the current payment systems, so adequate characterization of the payment system in the comparator practices will be important.

Outcome. Costs of combined services between the intervention and comparator organizations. Ideally, this will include costs to the practice, as well as costs to the organization. This would need to include both the cost per unit of service delivered and the overall costs per patient. Such “bundling” may or may not include inpatient care. The evaluation would also need to examine the quality of the services delivered in order to reassure providers and policymakers that payment bundling did not result in diminished care delivery. Patient and provider satisfaction would be a secondary outcome.

Timeframe. Presumably would need at least a 6 month run-in of the bundled payment system prior to initiating the evaluation of the services delivered. Time of evaluation would need to be at least 1 year.

Setting. Organizations utilizing integrated care. Given the unique characteristics of payment within the VA, this setting might be problematic, so community mental health settings would be optimal.

Study Design Considerations.

- Randomization at the level of the practice would be ideal, but may be organizationally difficult.
- The most feasible study design will be an observational study comparing organizations that are using bundled payment with those that are not. Organizations that are early adopters of bundled payment may be systematically different from later adopters. These factors would need to be addressed in data collection and analyses.
- Description of types of payment could be based on figure 13 from the 2008 AHRQ review2 (Appendix B), although this framework may need to be modified as new payment systems are developed.

### Research Need #7 Studies identifying the effectiveness of various components of integrated care, and determining the value added by each component individually and synergistically. What are the efficacious elements of integrated care?

Population. Individuals with mental health diagnoses seen in primary care settings using integrated care.

Intervention. An integrated approach to mental health care delivery. This should include some communication or coordination between providers to meet both the mental and general health needs of the patient. Each component of the integrated care system should be described in detail and might include such things as case identification through screening and referral, regular team meetings among providers (formal or informal), treatment plan consensus, co-location, joint decisionmaking, and electronic communication between providers.

Comparator.

A. Usual or routine care likely including simple referral of mental health patients to specialty mental health settings.
B. A similar integrated approach but with one of the key components removed. For example, the intervention might include case identification, co-location, and regular team meetings between providers and the comparator may include just case identification and co-location without regular team meetings.

Outcomes. To identify the key components of successful integrated programs, the outcomes of interest should reflect the various components under investigation. In the example above, the importance of team meetings for successful integration could be assessed relative to usual care by comparing the number of patients screened and subsequently treated within the program, as well as patient-centered health outcomes such as symptom severity, response and remission rates, health-related quality of life, and patient as well as provider satisfaction.

Timeframe. This study question requires examining established programs in place for at least 12 months and preferably 3 years or longer.

Setting. Primary care clinics implementing mental health integration practices.

Study Design Considerations. A number of study designs could be considered to answer this question.

- In theory a randomized trial could be designed to test various components in a four-cell matrix of integrated care but this would likely be expensive given the variety of approaches and individual components in question. The differences between the intervention and comparison groups are likely to be modest, necessitating large sample size, up to 80 practices and 12,000 patients (see power analysis). Descriptive case studies may be a more feasible option to identify program components included/excluded in successful and unsuccessful integration programs. Both qualitative and quantitative information could be used. Qualitative information would include interviews with practitioners, patients, and administrative staff to discern which program elements were vital to success and which were incidental. Cost and administrative complexity of the intervention components are also considerations.
- As with research need #5, the main focus will be on lessons learned from successful implementation. Sample sizes will not need to be large but different types of interventions will need to be examined.

### Research Need #8 Cost-effectiveness of integrated models from the societal perspective

Population. Either (a) individuals with mental health diagnoses seen in primary care settings or (b) individuals with medical comorbidities seen in specialty mental health settings. These could include both adults and children, although studies addressing those two populations would likely be conducted separately in each setting.

Intervention. An integrated approach to mental and general health care delivery.

Comparator. Usual care likely including simple referral of (a) primary care patients with mental health needs to a specialty mental health setting or (b) specialty mental health patients with medical comorbidities to a primary care setting.

Outcomes. Costs and clinical outcomes including benefits and harms could be assessed using disease-specific measures such as the cost per depression-free day or the cost per emergency department visit or hospitalization avoided.

Timeframe. To adequately evaluate costs, benefits, and harms a minimum of 6 months would be required, but longer time horizons would be preferred. A lifetime horizon is optimal to evaluate all costs, benefits, and harms.

Setting. Primary care practices with the capacity to deliver an integrated model of care. As noted above, studies of practices treating adults and children would likely be separate.

Study Design Considerations.

- A cost-effectiveness analysis conducted from the societal perspective using the cost per quality-adjusted life year (QALY) as the outcome measure. Depression-free days (or its counterpart for other conditions) can be cross-walked to QALYs. Cost per QALY could be assessed using incremental cost-effectiveness ratios, the net benefits framework, cost-effectiveness planes, and acceptability curves. Clinical characteristics of the patients should extend beyond depression, which has formed the basis of most of the studies in the past. The clinical characteristics of the patients should be assessed, since the cost-effectiveness of the integrated care intervention may vary depending on the case mix and severity of the mental health problems addressed.
- The “societal perspective” in this case may be close to the perspective of the insurer, but a true societal perspective will also include assessments of indirect costs, such as cost of time off work and disability payments.

### Research Need #9 Studies examining the business case for integration. When a practice or system invests in integrated care staffing and services, what are the revenues generated, and what are the effects on downstream costs such as hospitalization?

Note. Studies could take the perspective of the practice, the health care system, or the payer.

Population. Practices implementing integrated care. The clinical population could be either single diagnosis, such as depression, or be composed of care for multiple diagnoses such as depression and asthma, diabetes, or congestive heart failure. The population could include adults or children. However, it is important that the population be described in terms of demographics and clinical characteristics so that the generalizability of the research can be assessed.

Intervention. Integrated care of patients with mental health diagnoses in primary care, or primary care for patients with mental health diagnoses in specialty mental health clinics.

Comparator. No specific comparator needed for this “business case” study, since it is descriptive of how integrated care functions.

Outcome. Revenues generated from conducting integrated care minus the expenditures of that care. The revenues generated could be fee-for-service, or could be partial capitation or “gainsharing,” in which a portion of funds saved from reduced hospitalization or emergency department use is returned to the practice.

Timeframe. At least 1 year of run in of the integrated care intervention with duration of observation of at least 1 year.

Setting. Practices conducting integrated care.

Study Design Considerations.

- As noted above, these are observational studies. Given the variability in integrated care and the patient populations treated, adequate description of the intervention and patient case mix will be critical. The business case may be more readily achieved among patient populations who are more severely mentally ill, since they are the highest-cost patients.
- The number of cases for study will likely need to be at least 8, in order to assess variability across practice size, patient case mix, and type of organization. If great variation in business case results is found, more case studies may be needed.

### Research Need #10 Effectiveness of measurement-based integrated care for case identification, treatment, and monitoring, focusing on mental health conditions other than depression

Population. Patients with common mental health diagnoses other than depression seen in primary care practices. These might include anxiety disorders (including posttraumatic stress disorder [PTSD]), general/social phobias, and substance dependence (or substance use disorders).

Intervention. Identification of the patients and assessment of response to treatment using valid short instruments. Developmental work may be needed to test systems for care managers or others to identify patients. One approach would be to conduct a general mental health screening followed by more condition-specific use of diagnostic instruments.

Comparator. Integrated care models that do not use these instruments, in which the primary care clinicians and mental health professionals are reaching diagnoses and assessing progress using clinical judgment.

Outcome. Number of patients with the disorders of interest identified. The ability of the practice to monitor their progress, assessed through provider interviews. Valid tools to assess the response of patients to treatment will be needed.

Timeframe. At least 1 year. As with most organizational interventions, one would need at least a 6 month run-in time for the practice to gain familiarity with integrated care.

Setting. Primary care practices in both the intervention and comparator groups that have already established integrated care programs. The test here is of measurement-based care for these diagnoses when treated in an integrated care practice, not integrated care itself.

Study Design Considerations.

- These studies presuppose that short screening and measurement tools exist for diagnoses such as anxiety disorders, posttraumatic stress, and others. As such tools are developed, integrated care settings are obvious settings for testing.
- Clinical outcomes for the patients would need to be assessed using valid instruments, but the treating clinician would need to remain masked to the study instrument outcomes in order to prevent contamination of the comparator group. Ethical and practical issues of such masking will be significant design issues.
- Intervention would need to be at the level of the practice, not the provider, in order to avoid contamination of the comparator group.
- Randomized trial design, with the randomization occurring by practice, would be optimal.

### Research Need #11 Effectiveness of integrated care for patients with dual Medicaid and Medicare

Population. Dual Medicaid and Medicare patients with mental health diagnoses.

Intervention. An integrated approach to mental health care delivery. This should include communication or coordination between providers to meet both the mental and general health needs of the patient.

Comparator.

A. Usual care likely including simple referral of mental health patients to specialty mental health settings for mental health treatment or from mental health settings to primary care for general medical health treatment.
B. Nondual eligibles receiving the same integrated approach to mental and general health care delivery. Such patients are likely to be higher socioeconomic status, even if Medicare recipients, and measures to control for these differences will be needed.

Outcomes. Process of care outcomes might include number of patients screened for common mental health disorders, number of patients receiving some form of guideline-concordant psychological and/or pharmacologic treatment, number of patients receiving disease-specific mental health education and/or self-management advice, and availability of mental health providers.

Patient-centered outcomes could include symptom severity, response and remission rates, quality of life measures, adherence, and patient satisfaction.

Timeframe. To evaluate effectiveness, a minimum of 6 months of intervention time would be required.

Setting. Primary care clinics treating dual Medicare and Medicaid patients with mental health diagnoses.

Study Design Considerations.

- There could be several study designs to enhance understanding of integrated care for patients with dual Medicaid and Medicare eligibility. Subgroup analysis of dual eligibles could be conducted within a larger trial or observational study. Ideally the population of dual eligibles would be defined in advance and intended as a subgroup question. The difficulty with such studies is having enough power to answer a secondary question.
- A meta-analysis of subgroup data across existing trials has the advantage of providing adequate power by pooling data from different sources including small inadequately powered studies.
- Secondary data analysis of large datasets offers a potentially efficient and cost-effective method of studying integrated care for patients with dual Medicaid and Medicare eligibility. Datasets might include national comorbidity data, Substance Abuse and Mental Health Data Archive (SAMHDA), and linked Medicare and state Medicaid data sets.

### Research Need #12 Effectiveness of integrated care in the presence of both general medical comorbidities such as diabetes or chronic pain, as well as mental health comorbidities, such as depression and anxiety

Population. Patients with comorbid serious mental health and general medical conditions seen in primary care. Serious mental illnesses might include schizophrenia and bipolar disorders as well as other psychotic disorders. General medical conditions might include obesity, diabetes, hepatitis C, coronary heart disease, arthritis, hypertension, and chronic obstructive pulmonary disease as some of the more common co-occurring general medical conditions seen in this population.

Intervention. An integrated approach to mental health care delivery. This should include communication or coordination between providers to meet both the mental and general health needs of the patient.

Comparator. Usual or routine care likely including simple referral of serious mental health patients to specialty mental health settings.

Outcomes. Both the mental and general health outcomes would be of interest. Process of care outcomes might include number of patients with chronic conditions screened for common mental health disorders, number of patients receiving some form of psychological and/or pharmacologic treatment, number of patients receiving disease-specific mental health education and/or self-management advice, proportion of NQF quality measures for those conditions achieved, and availability of mental health providers.

Patient-centered outcomes could include symptom severity, response, and remission rates for both the mental and general medical conditions, quality of life measures, adherence, and patient satisfaction. For diabetes, for example, measures would include hemoglobin A1C, blood pressure control to a level of systolic less than 140, and control of low-density lipoprotein levels.

Timeframe. To evaluate effectiveness, a minimum of 6 months of intervention time would be required.

Setting. Primary care clinics treating patients with co-occurring mental and general medical diagnoses.

Study Design Considerations.

- There could be several study designs to enhance understanding of integrated care for patients with comorbid mental and general medical conditions. An obvious design would be subgroup analysis within a larger trial or observational study, ideally powered to answer the secondary question.
- A meta-analysis of subgroup data across several trials could answer this question and has the advantage of providing adequate power by pooling data from different sources including small studies. Whether the component studies could support such a meta-analysis would need to be assessed.
- Secondary data analysis of large datasets offers a potentially efficient and relatively low-cost method of studying integrated care for patients with dual comorbid mental and general medical conditions. Drawing information on medical conditions from an electronic medical record would also have efficiency advantages.

Randomized trials would require randomization at the level of the practice, with analysis using clustered methods. Randomization at the level of the individual would likely be administratively infeasible and place the study at risk of contamination. The primary unit of analysis in such studies would be at the level of the patient. Sample size would depend on the size of any practice effects, since patients are clustered within practices. Sample size would also depend on the outcome measure used. Observational studies with control for clinic and patient characteristics are another option, but with the challenge of case mix adjustment and assessment of comorbidity between practice settings.

### Research Need #13 Effectiveness of the medical home as a model/strategy for integrated care

Note. The “medical home” could be a primary care office for many patients, but could also be a specialty mental health practice with elements of primary care integrated to form the medical home.

Population. Patients with mental health conditions including depression and anxiety disorder treated in patient-centered medical home (PCMH) practices. Some specialty mental health practices might have characteristics of a PCMH if they are integrating components of comprehensive medical care with the mental health care provided. Patients in specialty mental health practices will be much more likely to have serious mental disorders such as schizophrenia and bipolar disorder.

Intervention. The patient-centered medical home. While multiple definitions exist, the NCQA “level 3” certification is commonly accepted as representing an advanced level of care delivery and coordination.

Comparator. Two comparator groups could be considered:

A. Primary care practices that do not consider themselves “patient-centered medical homes” or that are not NCQA-certified as PCMHs. It is highly unlikely that specialty mental health settings currently consider themselves “medical homes;” studies of those settings are most likely to be descriptive.
B. Usual care in either the primary care or the specialty mental health setting.

Outcomes. Determination of the extent to which the PCMH incorporates the principles of integrated care for mental health conditions. Determination of the extent to which specialty mental health practices incorporate PCMH principles into their care. The extent to which quality of care measures are met. Remission of symptoms among patients with mental health diagnoses.

Timeframe. An initial study would be cross-sectional, determining whether PCMH practices are in fact delivering integrated care for patients with mental health diagnoses. Studies to determine the effectiveness of PCMHs in treating mental health conditions would need to be conducted for at least 1 year.

Setting: Primary care practices that are NCQA PCMH level 3 accredited. Specialty mental health practices that are integrating general medical care into their practices.

Study Design Considerations:

- A scan of gray literature on the topic might be helpful since the concept of medical home is relatively new as a model for integrated care.
- Surveys of current PCMH accredited practices could be conducted, comparing their activities with those of primary care practices using integrated mental health care principles. If the PCMH practices are not addressing mental health issues, then conducting a study comparing the outcomes would likely not be very productive. Assuming that they are addressing mental health issues, cross-walking the principles of care management will be very useful, since similar practices may use different terminology.
- Only after the first several steps are taken will it be wise to conduct cohort studies comparing the outcomes of patients with depression or other mental health diagnoses seen in PCMH to those of patients seen in integrated care practices that do not consider themselves PCMH. The initial steps will assist in refining the data elements to be collected and analyzed. Randomization would very difficult given the complexity of PCMH accreditation.

## Dissemination Gap

We note one topic that stakeholders ranked as high priority in the initial round of voting but that is not included in the above list: the need for a resource where researchers and policymakers can go to identify existing programs that already show return on investment related to different levels of integration. We excluded this topic from the second round of prioritization because it is not a research topic per se, but we consider the issue to be noteworthy and needed.

## Power Analysis

The table below shows the results of power analyses that were conducted based on the assumptions described in the Methods section, using the formulas proposed by Spybrook and colleagues13 for cluster randomized trials. Where the projected number of patients per practice is greater than 1,000, the number of clusters and the cluster size are omitted from the table.

Between-site variation in effect size | Effect Size | Clusters | Approx. n per cluster | N
0.05 | 0.3 | 40 | 17 | 680
0.05 | 0.3 | 60 | 9 | 540
0.05 | 0.3 | 80 | 6 | 480
0.05 | 0.15 | 40 | — | —
0.05 | 0.15 | 60 | — | —
0.05 | 0.15 | 80 | 161 | 12,880
0.12 | 0.3 | 40 | — | —
0.12 | 0.3 | 60 | 19 | 1,140
0.12 | 0.3 | 80 | 9 | 720
0.12 | 0.15 | 40 | — | —
0.12 | 0.15 | 60 | — | —
0.12 | 0.15 | 80 | — | —

For a comparison of mental health outcomes in primary care practices, assuming ES=0.3 and ICC=0.05, the required sample size would be about 500–700 patients and 40–80 practices, with at least 6–17 patients per practice (depending on the number of practices). Assuming a smaller effect size (ES=0.15, ICC=0.05), it would be impractical to conduct a trial (e.g., with 80 practices, such a study would require 161 patients per practice, or a total sample size of 12,880). This is relevant especially for research needs #3 and #7, which could be expected to involve small treatment effects. Power could be increased by adding practice-level covariates or by reducing the between-site variation in the treatment effect. However, a more detailed power analysis would be required, and it would be very important to meet the assumptions specified in the research design phase.

Assuming greater between-site variation in the treatment effect (ES=0.3, ICC=0.12) also reduces power, but it would still be practical to conduct a trial with about 700–1,200 patients and 60–80 practices, with at least 9–19 patients per practice (depending on the number of practices).

Given the possibility that assumptions may be incorrect, it would be wise for a cluster randomized trial to include at least 60–80 practices if possible, to measure relevant practice-level covariates, and to make every effort to reduce between-site variation in the treatment effect.

The results reported above are intended to convey only general information about the types of study designs that could (or could not) be used to meet research needs. For example, these power analyses do not take into account the testing of interaction effects. For trials designed to test the effects of interactions between person-level characteristics and the treatment effect (as in research need #11 on dual eligibles), the required sample sizes may be larger than those reported above. Because the power calculations for multilevel models involve complicated formulas, simulation may be a preferred method of power analysis for models that include interaction terms or have other complex features. The study team recommends that for any new trial being contemplated, the investigators conduct a separate, detailed power analysis specific to the proposed study.

## Modified Analytic Framework

Using figure 1 from the 2008 AHRQ review (Appendix I) as an analytic framework, we developed a modified framework linking the identified future research needs to specific characteristics and processes of care (Figure 1) Some future research needs related to more than one area.

Figure 1 Relationship between future research needs and analytic framework for integrated care

Figure 1 (Relationship between future research needs and analytic framework for integrated care). Is a flowchart depicting a modified analytic framework linking identified research needs to specific characteristics of integrated models of care and processes of care. At the bottom of the figure is a rectangle with the list of 13 future research needs identified in the paper. The flowchart is a set of 6 rectangles arranged in 2 rows and 3 columns; an additional set of 6 rectangles lists the specific research needs that relate to each of the rectangles. The top row of 3 rectangles lists (from left to right) the characteristics of integrated models: “Systematic screening”; “Integrating providers”; and “Integrated care/proactive followup.” Arrows point downward from each of the top rectangles to the particular rectangle in the bottom row that relates to each characteristic. For example, “Systematic screening” points to “Identify mental health problem”; “Integrating Providers” points to “Primary Care Providers or Primary Care/Mental Health Provider Teams: Awareness of mental health problems; comfort treating mentally ill patients and/or coordinating services with mental health providers for complex patients; and adherence to evidence based guidelines.” And finally, “Integrated care/proactive followup” points to “Patients: access to care, reduced stigma, engagement in care, and adherence.