# References

1 Unutzer J, Schoenbaum M, Druss BG, et al. Transforming mental health care at the interface with general medicine: report for the presidents commission. Psychiatr Serv. Jan. 2006;57(1):37-47. [pmid: 16399961].
2 Butler M, Kane RL, McAlpine D, et al. Integration of mental health/substance abuse and primary care. Evid Rep Technol Assess (Full Rep). Nov. 2008;(173):1-362. [pmid: 19408966].
3 Wang PS, Lane M, Olfson M, et al. Twelvemonth use of mental health services in the United States: results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. Jun. 2005;62(6):629-640. [pmid: 15939840].
4 Young AS, Klap R, Shoai R, et al. The quality of care for depressive and anxiety disorders in the United States. Arch Gen Psychiatry. 2001;58:55-61. [pmid: 11146758].
5 Nasrallah HA, Meyer JM, Goff DC, et al. Low rates of treatment for hypertension, dyslipidemia and diabetes in schizophrenia data from the CATIE schizophrenia trial sample at baseline. Schizophr Res. 2006;86:15-22. [pmid: 16884895].
6 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
7 Dietrich AJ, Oxman TE, Williams JW Jr, et al. Going to scale: re-engineering systems for primary care treatment of depression. Ann Fam Med. Jul–Aug. 2004;2(4):301-304. [pmid: 15335127].
8 Dietrich AJ, Oxman TE, Williams JW Jr, et al. Re-engineering systems for the treatment of depression in primary care: cluster randomised controlled trial. BMJ. Sep 11. 2004;329(7466):602. [pmid: 15345600].
9 Chinn S. A simple method for converting an odds ratio to effect size for use in meta-analysis. Stat Med. Nov 30. 2000;19(22):3127-3131. [pmid: 11113947].
10 Druss BG, Rohrbaugh RM, Levinson CM, et al. Integrated medical care for patients with serious psychiatric illness: a randomized trial. Arch Gen Psychiatry. Sep. 2001;58(9):861-868. [pmid: 11545670].
11 Rush AJ, Fava M, Wisniewski SR, et al. Sequenced treatment alternatives to relieve depression (STAR*D): rationale and design. Control Clin Trials. Feb. 2004;25(1):119-142. [pmid: 15061154].
12 Raudenbush SW, Liu X. Statistical power and optimal design for multisite randomized trials. Psychol Methods. Jun. 2000;5(2):199-213. [pmid: 10937329].
13 Spybrook J, Raudenbush SW, Congdon R, et al. Optimal Design for Longitudinal and Multilevel Research: Documentation for the “Optimal Design” Software. 2009. Accessed August 5, 2010. Available at http://www.wtgrantfoundation.org/resources/overview/research_tools.
14 National Institute of Mental Health, Seattle Children’s Hospital. Telemental health to improve mental health care and outcomes for children in underserved areas. 2010. Accessed July 28, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00830700.
15 National Institute Mental Health (NIMH). Integrated telemental health intervention for depression in primary care. 2009. Accessed July 28, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00719979.
16 National Institute Mental Health (NIMH). Pilot trial of depression care management by electronic secure messaging. 2009. Accessed July 28, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00755235.
17 National Institute Mental Health (NIMH), Department of Veterans Affairs. Telemedicine outreach for post traumatic stress in CBOCs. 2010. Accessed July 28, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00821678.
18 National Institute of Mental Health, Massachusetts General Hospital. Effectiveness of telepsychiatry-based culturally sensitive collaborative treatment of depressed Chinese Americans. 2010. Accessed July 28, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00854542.
19 Logsdon MC, Foltz MP, Stein B, et al. Adapting and testing telephone-based depression care management intervention for adolescent mothers. Arch Womens Ment Health. Aug. 2010;13(4):307-317. [pmid: 20020164].
20 Medicare Payment Advisory Commission (MEDPAC). Report to the congress. New approaches in Medicare. June. 2004.
21 Donohue J. Mental health in the Medicare Part D drug benefit: a new regulatory model?. Health Aff (Millwood). May–Jun. 2006;25(3):707-719. [pmid: 16684735].
22 Bachman J, Pincus HA, Houtsinger JK, et al. Funding mechanisms for depression care management: opportunities and challenges. Gen Hosp Psychiatry. Jul–Aug. 2006;28(4):278-288. [pmid: 16814626].