# Methods

## Identifying Research Gaps from the 2008 AHRQ Review

Investigators from the RTI–UNC EPC initially examined the original 2008 AHRQ systematic review and contacted the authors for collaboration and advice. The original table of research gaps contained in the 2008 report was supplemented with research gaps identified in the text of the original report.

## Identifying Recently Published and Ongoing Studies

We conducted a scan of the literature published on integrating mental health with primary care since 2008 (search strategy in Appendix C) and found an active research area, with 942 relevant citations, 70 of which were found to be relevant publications likely to have met inclusion criteria for the original report (Appendix D). Publications were identified through searches of Medline, Cochrane, CINAHL, and PsycINFO. We used the literature scan to demonstrate activity in the field within the research gaps identified by the 2008 report. Titles and abstracts identified were dually reviewed, and each eligible study was assigned to a research gap from the 2008 report.

Ongoing research projects were identified through searches of clinicaltrials.gov, NIH REPORTER, HSR PROJ, and the Public Welfare Foundation grants database. In addition, as part of the US Department of Health and Human Services, the Health Resources and Services Administration (HRSA) Web site was searched for relevant ongoing studies, as were the following National Institutes of Health (NIH) Web sites: National Institute of Mental Health (NIMH), National Institute on Alcohol Abuse and Alcoholism (NIAAA), National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS), National Cancer Institute (NCI), National Institute on Drug Abuse (NIDA), and the Clinical and Translational Science Awards (CTSA) consortium. Each research abstract was dually reviewed by the RTI-UNC EPC investigators and staff to determine relevance to the area of integrated care in mental health and subsequently mapped to the research gap it might fill.

We did not present the stakeholders with the results of the literature search prior to the priority-setting exercises, since we had not assessed the quality of individual studies and the strength of the new evidence and were not therefore in a position to determine if recent evidence has filled research gaps identified in the 2008 report.

## Prioritizing Research

We used several methods to prioritize research gaps: a combination of teleconference, online web meetings, email, and web-based prioritization exercises (Appendix E). We convened stakeholders during two meetings, conducted two online prioritization exercises, and received additional feedback by email.

We provided stakeholders with the 2008 report and asked them to focus on the 19 identified gaps from that report. During this process of prioritization, we asked the stakeholders to consider their knowledge of the field, the original 2008 AHRQ review, AHRQ’s Effective Health Care Program selection criteria for new research proposed by the AHRQ Scientific Resource Center (Appendix F),6 and the matrix of integration levels outlined in Appendix G. For additional consideration, we also provided stakeholders with a list of ongoing research projects in the area of mental health and integrated care, identified by the initial research gap the study might be able to fill (Appendix D). During an initial conference call discussing the purpose of the project, the stakeholder group discussed the initial list of research gaps. The EPC had also identified additional gaps from the text of the report that were not fully reflected in the table. The stakeholder group recommended several additional gaps for consideration that we subsequently added to the list, bringing the total number of gaps to 40 (Appendix H). We felt that this number was too many to be useful as a “priority list,” because of potential overlap in topics that might have led to vote-splitting, variation in types of priorities, and magnitude of topics. We conducted an online priority-setting exercise where we presented the stakeholder panel with the 40 non-rank-ordered research gaps and asked them to rate the gaps twice, using different methods. First, we asked stakeholders to use a 5-point Likert scale of “importance” to determine whether each gap was of low or high priority for future research, and second, we provided an online forced prioritization exercise where we assigned each stakeholder a total of “20 chits,” of which a maximum of 5 chits could be assigned to any one gap.

We held a second call/Web meeting (using GoToMeeting^®^ technology) to review the initial findings and refine the original list. Based on results from the first prioritization exercise and discussions from the second call, we refined the list of 40 gaps further and reduced it to a total of 20 gaps. We eliminated some gaps that had received zero or only one vote as low priority areas, and combined and reworded others for greater clarity. We shared these modifications with the stakeholders. Appendix F lists the final list of 20 gaps that were carried forward for stakeholder prioritization.

The second round of prioritization also utilized an online exercise. The Likert scale exercise was found to have minimal usefulness in prioritizing gaps; the stakeholders indicated that almost all of the gaps were of moderate or high importance. Although this finding did reassure us that we had identified important gaps, the Likert scale was not useful in distinguishing among the gaps and was not employed for this second round of prioritization. Instead, stakeholders were presented with an online, nonranked list of 20 gaps and provided a total of 12 chits to assign to gaps, 4 of which could be used for any one gap.

The results from the second exercise formed the basis of the final prioritized list for development as future research needs. The final list of 13 gaps incorporated all gaps chosen two or more times by stakeholders. Each was developed as a potential future study with PICOTS and an outline of study design considerations.

## Engaging Stakeholders, Researchers, and Funders

The RTI–UNC team worked with AHRQ and the authors of the 2008 review in the identification and recruitment of stakeholders, including advocacy groups, researchers, providers of care, federal government funders of research, and professional organizations. We developed and refined a list of stakeholders and recruited them in the first two months of the project. A variety of methods were employed to select stakeholders. These included ensuring representation from a broad spectrum of organizations and interest groups, and engaging stakeholders with a range of perspectives. One major innovation with this effort of stakeholder engagement is the presence on the stakeholder panel of federal agencies as research funders. On two occasions, the first individual contacted had time constraints or felt they were not the best choice and worked with us to recruit a panel representative elsewhere in their organization. One organization did not respond to several invitations. Several levels of approval needed to take place prior to the federal stakeholders joining the project, perhaps owing to the newness of the initiative.

## Role of Stakeholders

The primary role of the 10 stakeholders for this project was to rank order or prioritize research gaps in the area of integration of mental health and substance abuse and primary care from the many gaps identified in the 2008 AHRQ report. Stakeholders informed the original list of gaps, refined the list through a series of discussions and online exercises, and prioritized the final list. To provide the opportunity for input at multiple times and through several mechanisms, we used moderated group discussions, email, and anonymous online prioritization exercises to solicit input.

This working document will be made available by AHRQ for public comment and input.

## Handling Conflicts of Interest

Each potential stakeholder completed a conflict of interest form. Forms were reviewed by both the RTI–UNC EPC and AHRQ for potential conflicts of interest. Had a substantial conflict of interest been discovered, the stakeholder would have been considered ineligible for participation on the panel and another stakeholder would have been approached in his/her place. To avoid any unfair advantage resulting from potential future RFAs arising from this report, the stakeholders prioritized the final list of gaps individually and were not privy to the final rank order prior to publication of the report for public comment.

## Determining Appropriate and Feasible Study Design

After the stakeholders prioritized the research gaps, the study team developed the future research needs through elaboration of PICOTS (population, intervention, comparator, outcome, timeframe, setting) for each of the 13 prioritized areas. We evaluated potential study design considerations for each of the prioritized future research needs against specific criteria such as stage of research, generalizability, feasibility, cost-effectiveness, and ethics. Study design options were generated and refined over several rounds by the multidisciplinary study team, which included methodologists, analysts, and mental health service researchers, drawing on the expressed priorities generated by the stakeholder group. For instance, we suggested demonstration pilots for studies that require preliminary data on acceptability and feasibility before considering large studies or trials. We considered case studies where testing is necessary across multiple settings. When outcomes are available from claims data, we suggest secondary data analysis as a cost-effective method of using existing data to study identified outcomes. When controlled trials may be unethical or infeasible due to high costs and difficulty enrolling patients we suggested observational studies. We suggested randomized trials when practical and feasible for studies looking at the efficacy of one treatment or system compared with another. Several future research needs could be addressed by more than one study design; we anticipate that the study design implemented could in part depend on study setting, administrative feasibility, and funding availability. Choice of clinical and organizational outcome was derived from the team’s knowledge of the literature, experience with similar studies, and judgment as to the most efficient way of addressing the research need. The timeframe chosen for the study was also generated from the team’s research experience and knowledge of organizational change in practices. We determined trial feasibility by conducting power analysis and examining the practicalities of clustered randomization, contamination, setting, and timeframe. Meta-analysis was considered where it might be appropriate to combine trials, which would provide a way to perform subgroup analysis on a large sample.

We conducted power analyses based on several hypothetical designs for cluster randomized trials that would fit one or more of the research needs outlined in this report. The objective was to determine the approximate numbers of practices and patients needed in order to have power of 0.80 to detect a clinically meaningful difference in outcomes with a two-tailed test at a significance level of 0.05. Separate analyses were conducted for hypothetical trials with 40, 60, and 80 clusters (i.e., 20, 30, and 40 practices in each treatment arm).

We used various assumptions for the treatment effect size and the amount of variation between sites in the treatment effect. With regard to treatment effect sizes for mental health outcomes in primary care practices, we used the Re-Engineering Systems for Primary Care Treatment of Depression (RESPECT-D) study as a reference point because it used a cluster-randomized design, the study population was similar to the general population of patients with depression, and the intervention was relatively modest in scope.7,8 In that study, the power analysis was based on an effect size of 0.3, and in fact the authors found 6-month effect sizes of 0.31, 0.29, and 0.35 for depression severity, response, and remission, respectively. (For response and remission, both dichotomous outcomes, odds ratios [ORs] were converted to standardized effect sizes [ESs] using ES=ln(OR)/1.81.^9^) Therefore an effect size of 0.3 was assumed for cluster randomized trials comparing the mental health outcomes of integration to those of usual care in primary care practices. This effect size is similar in magnitude to the lower bounds of the 95% confidence intervals for the 3-month and 6-month effects measured in the IMPACT study.2 It is also smaller than the 12-month effect size of 0.51 reported by Druss and colleagues on the Short Form-36 Physical Component Summary (SF-36 PCS) in their study of integration in mental health specialty practices.2 Therefore the more conservative effect size estimate of 0.3 was used for medical outcomes in specialty mental health practices as well as for mental health outcomes in primary care practices. A smaller effect size of 0.15 was also used, in order to project the effect on required sample size when the treatment is expected to have lower impact (e.g., when individual components of integration are tested, as in research needs #3 and #7).

In a cluster randomized trial, assumptions about the amount of between-site variation in the treatment effect also influence projections of the required sample size. (Between-site variation in the treatment effect reduces statistical power.) Neither the RESPECT-D trial nor the study by Druss and colleagues reported intraclass correlations (ICCs).7,8,10 However, unpublished analyses by this study team of secondary data from the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) study11 (N=4,041) resulted in ICCs of 0.053 and 0.042, respectively, for baseline Quick Inventory of Depressive Symptomatology-Self Report (QIDS-SR-16) and Hamilton Rating Scale for Depression (HAM-D) scores among patients in primary care clinics, and an ICC of 0.12 for baseline PCS-12 scores among patients in mental health specialty clinics. Therefore, ICCs of 0.05 and 0.12 were used for the power analyses. The ICC of 0.05 represents a small amount of between-site variation, and the ICC of 0.12 is between medium (0.10) and large (0.15).12 Based on the power analysis findings, we added general notes on sample size to multiple discussions of design considerations in Appendix A. We concluded that several prioritized future research need projects required substantial numbers of both clinics and patients because the intervention effect sizes for those projects were expected to be modest.