# External Inputs

## Stakeholder Panel

Harold Pincus, M.D.

Columbia University

New York, NY

Annette DuBard, M.D., M.P.H.

Informatics, Quality, and Evaluation

Medicaid/CCNC

NC Community Care Networks, Inc.

Morrisville, NC

Joyce West, Ph.D., M.P.P.

American Psychiatric Association (APA)

Arlington, VA

Michael Fitzpatrick, M.S.W.

National Alliance on Mental Illness (NAMI)

Arlington, VA

Peggy Clark, M.S.W., M.P.A.

Disabled and Elderly Health Programs Group

Center for Medicaid & State Operations

Baltimore, MD

Dave Shern, Ph.D.

Mental Health America

Alexandria, VA

Kenneth S. Thompson, M.D.

Substance Abuse and Mental Health Services Administration (SAMHSA)

Rockville, MD

John Williams, M.D.

Duke University and Durham VA

Medical Center

Durham, NC

Kelly Kelleher, M.D., M.P.H.

The Research Institute at Nationwide Children’s Hospital

Center for Innovation in Pediatric Practice

Columbus, OH

Donald L. Weaver, M.D.

Office of Special Health Affairs

Health Resources and Services Administration

Rockville, MD