# Discussion

Systematic reviews can rarely answer all aspects of the key questions asked because of gaps in the reviewed research. Traditionally, future research needs are briefly summarized within a review with few concrete recommendations to inform researchers, funders, or policymakers. This pilot project sought to develop a structured approach to future research needs. The primary objective was to clearly identify gaps in a recent AHRQ review and to work with stakeholders to develop a prioritized list of potential future research, develop PICOTS, and discuss study designs for future consideration. The secondary objective was to work through the methods and processes of this pilot task as a means of identifying best practices for subsequent future research needs projects.

Regarding our primary objective, our findings suggest that future research in the area of integration of mental health and primary care should first focus on (a) identifying methods of integrating primary care into specialty mental health settings; (b) identifying cross-cutting strategies of integration across multiple mental health diagnostic categories as opposed to a separate strategy for each diagnostic category; and (c) examining the use of information technology for integrating mental and general medical health care. Other important priorities for future consideration include the sustainability of successful integration models, methods of disseminating integration programs into various settings, the business case for integration as well as methods of payment, the cost-effectiveness of integration, and the key components of successful strategies. The importance of sustainability and economic justification for integrated care strategies emerged as a theme throughout the prioritization process and during our conference calls with the stakeholders. The literature and the stakeholders indicated that the efficacy of integrated care was established; but that its ability to be sustained in everyday practice remains to be proved, and will in part depend on the level of incentives and support provided through payment system reform, as well as the ability of the practices to provide the care efficiently.

Regarding the methods and processes of this pilot project, we specifically focus on the value of processes: stakeholder engagement and sample size analysis. We were gratified by the engagement of the stakeholders, their practical knowledge of the field, and their enthusiasm to advance the science and service delivery to this at-risk population. The stakeholder group was diverse, including advocates, professional representatives, researchers, and funders. They were quite collegial and through their voting indicated a clear ability to set priorities when presented with a large number of options. All stakeholders were sent a copy of the draft report at the same time as it was released for public comment. One possible modification for future projects of this type would be a third set of rankings after the full PICOTS elaboration of the future research needs. This would allow the stakeholders to make more informed choices resulting in a more refined set of priorities, but it would also significantly prolong the project.

Although our initial list of research gaps included lack of information on diagnosis-specific integrated care (such as a specific study on anxiety disorders or problem drinking), the stakeholders did not consider such studies to be priorities. In discussion, they indicated that although the burden of illness caused by anxiety disorders (as an example) is large, the impracticality of implementing multiple condition-specific integration interventions in a single practice decreased the value of conducting such studies. Similarly, the stakeholders highly ranked cross-cutting integrated care interventions, by which multiple types of conditions could be managed in a practice using the same personnel and procedures. This finding underscores the utility of stakeholder involvement.

Although our final list of 13 research need statements was substantially reduced from the original list, the questions posed related to essentially all components of integrated care in mental health as described in the 2008 AHRQ report (Appendix I), including screening, integration of providers, formation of teams, followup, and patient issues. This distribution was not by design, and the analytic framework was not discussed during the stakeholder conference calls. We were impressed that the stakeholders identified a variety of topics, addressing multiple components of systems of integrated care, as priorities for future research. Because many of the future research need topics can be addressed through use of more than one study design, many studies could be derived from this priority list. We have illustrated the advantages and disadvantages of approaches in the sections on study design considerations. Final choice of study design by a researcher will likely include knowledge of the specific potential study settings, issues of administrative feasibility, time constraints, funds available, and expertise.

Our examination of sample size as one of the key study design considerations was useful. Some of the research gaps could be addressed relatively inexpensively through secondary data analysis or through case studies of 8–16 practices. Other questions, however, will require prospective data collection. At least two research gaps would necessitate comparing interventions which may have only a modest effect size difference between them, such as #3 comparing the addition of information technology to integrated care, or #7 comparing the various components of integrated care. When comparing two active interventions, each better than “usual care,” the effect size found between the two active interventions will generally be smaller than the effect size between the active intervention and usual care. This is a generalizable issue in comparative effectiveness research. When sample size calculations indicate the need for very large samples, a critical question that must be addressed is whether the importance of the question is worth the large investment in research funding and effort.

The following challenges and limitations of this pilot project are worth noting. Initial selection and engagement of stakeholders was often time-consuming, particularly in the case of federal stakeholders for whom several layers of approval were required. This may be a product of the fact that this was a new initiative and now that a process has been established may be less of a factor for future reports. Despite a fairly significant time commitment, stakeholders were not compensated because of concerns regarding conflict of interest. The absence of even modest compensation may become a problem if we need to engage the same stakeholders long-term for a variety of projects. Focusing stakeholders on the specific gaps identified in the report under review was sometimes challenging; there was a tendency to redefine the questions asked in the report or to pose questions that might be out of scope of the systematic review. Agreeing upon an initial list of research needs was also challenging; some needs were very broadly defined while others were quite specific. The decision to split or group research needs required much thought and is a potential limitation to the exercise. The risk, on one hand, is losing important research needs by combining gaps under broad headings; on the other hand, splitting may result in a list too long to be useful for the purpose of prioritizing. We felt that a relatively specific description of research gaps was best; broad research aims or goals may be difficult to operationalize. Nesting specific gaps under broad headings may be an alternative approach but this presents technological challenges for online voting, since stakeholders may interpret such nested lists differently. We began the process of prioritization with a large number (N= 40) of identified research gaps. Although we were able to significantly refine the questions posed by the gaps and reduce the number of questions through the prioritization process, we still had a large number of identified priorities which we elaborated in a PICOTS framework and discussion of sample size considerations. Given this large number of potential projects, we did not develop any “value of information” analyses; this would have substantially lengthened the project and probably not have provided substantial new information. We did, however, find the evaluations of effect size and sample size to be very useful.

The full report will be posted on the AHRQ Web site and public comments will be collected, including comments from the stakeholders.