# Conclusions

As a pilot project, we engaged stakeholders, developed a process for prioritizing future research, elicited priorities from the stakeholders through an iterative process, and developed a framework for considering the most feasible study designs to employ for each identified research need. We were able to identify 13 potential future research projects in the area of integrated care, with details regarding the study design options within the PICOTS framework. We found that the stakeholders were able to prioritize, but the number of research needs was quite large, leading to limitations in the level of study design detail in this report. The research needs of integrated care in mental health has moved past demonstration of efficacy to address issues of implementation, effectiveness, sustainability, utilization of technology to reduce costs, extension of the successful integrated care models to specialty mental health settings, and to clinical conditions beyond depression. Many of the studies discussed in the research need priority areas, such as the examination of cost-effectiveness and sustainability, can be implemented at modest cost. Key will be conducting the studies in generalizable settings and with early communication with the user community. The level of public and policy interest in this area will necessitate continued relatively rapid translation of these research gaps into studies and then to policy implementation.