# Background

Mental health problems are among the most common problems encountered by primary care providers.3 Half of the care for common mental disorders in the United States is delivered in general medical settings.1 Primary care providers commonly diagnose and manage conditions such as dysthymia, major depressive disorder, problem drinking, and anxiety disorders. Multiple challenges exist in delivering high-quality mental health care in primary care settings.4 The quality of the care delivered in the primary care setting may vary: providers may have difficulty making referrals when needed to mental health professionals; the supply of mental health professionals may be inadequate in some areas; and patients may be reluctant to see a second provider. Patients with serious and persistent mental illness such as schizophrenia are often seen predominantly in specialty mental health settings yet often have substantial unmet general health needs including obesity, diabetes, and cardiac risk factors, sometimes exacerbated by medication treatment of their mental illness.5

“Integrated care” is one approach to addressing these currently unmet needs. In integrated care models, there is systematic linkage of mental health and primary care providers requiring communication or coordination between providers to meet both the mental and general health needs of the patients.2 The exact nature of the consultation and collaboration varies greatly across models, and may include telephonic or information technology. Often, a mental health professional is placed, permanently or intermittently, in the primary care practice. A key difference is that the integration implies a much closer and more coordinated system of care than prior consultation or referral models. Also key is the involvement of a second health care professional, which distinguishes integrated care from interventions that train primary care providers to treat patients with mental health conditions without the involvement of a mental health professional.

In 2008, the Agency for Healthcare Research and Quality (AHRQ), working with the University of Minnesota Evidence-based Practice Center (EPC), conducted a systematic review of the literature evaluating the integration of mental health and substance abuse treatment with primary care. The review addressed six key questions. A summary of the 2008 report’s conclusions, findings, limitations, and future recommendations is listed in Table 1.

Table 1 Summary of findings, limitations, and recommendations from the 2008 AHRQ review (modified using table 19 of the original report2)

Key Question | Results of Literature Review | Limitations | Future Research Recommendation
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes? | - Multiple models have been used and most show positive results; - Level of integration is not related to outcomes; - Most models integrate mental health into primary care; fewer do the opposite | - Most of the evidence is for treatment of depression in primary care settings | - Test explicit variations; - Compare integrated care to systematic practice; - Expand coverage of mental health problems beyond depression (substance abuse, anxiety, multiple mental illnesses); - Test for fidelity of integration principles, evidence-based intervention, communication among clinicians, followup to what is delivered
2. To what extent does the impact of integrated care programs on outcomes vary for different populations? | - Most of the work has been done with older patients; - Some positive results with minority populations | - Little available research on the impact of integrated care on younger populations, rural populations, or for those with serious and persistent mental health conditions | - Who is most likely to benefit from this type of care?; - Will this approach work with children and adolescents?; - Will this model work in rural settings?; - Can such practices afford a health manager?; - Is this approach consistent with cultural values of various minority groups?
3. What are the identified barriers to successful integration and sustainability? | - Costs and coverage; multiple payers, each with their own rules; - Most practices involved were volunteers; may not be typical of practices in general; - Poor payment for care coordinators | - The findings failed to show evidence of the sustainability or generalizability of various integrated models | - More models of integrated payment needed; - How generalizable is this practice?; - Can consistent patterns of care be sustained?
4. To what extent did successful integration programs make use of health information technology (IT)? | - Minimum use of IT | - Little is known about the use of IT in integrated models of care | - How can IT be better used to support integrated care?; - Does the use of IT improve outcomes in integrated care?; - Could telephonic mental health consultations be enhanced with integrated IT systems
5. What financial and/or reimbursement structure was employed in successful integration programs? Is any specific financial/reimbursement strategy superior to another? | - See KQ 3 | - Little was found on financial models for integrated care | - What is the business case for integration?
6. What are the key elements of programs that have been successfully implemented and sustained in large health systems? | - VA offers a good model of sustained program; - Active support at all levels; - Special funding | - While the research found overall improvement in health outcomes with integrated care, few studies examined key elements for success | - What elements of integration are vital?; - Do the standard elements of successful continuous quality improvement (CQI) implementation pertain here?

The Minnesota EPC authors found 33 trials examining the impact of integrating mental health specialists into primary care; 26 trials addressed depression. The studies reported positive results for symptom severity, treatment response, and achievement of remission when compared with usual care. The level of care integration did not seem to be related to treatment outcomes. The EPC authors also reported that the level of integration did not appear to be related to outcomes. Most of the studies addressed the integration of mental health professionals into primary care; few examined the integration of primary care into mental health. A majority of the studies have involved older patients, and some positive studies, having found improved outcomes with integrated care, have been largely composed of minority populations. The main barriers identified to a broader use of integrated care include programmatic costs, insurance coverage, and relationships with multiple payers. The VA was felt to offer a good model of a sustained program. Key elements of successful models included active support at all levels of the organization and specific funding.

The authors of the 2008 AHRQ review reported on a number of gaps/limitations (summarized in Table 1, reproduced from the original report). Several gaps identified little prior research in conditions other than depression or examined care integration in younger populations. Other gaps included little research in rural areas, little examination of the use of information technology, or little development of financial models. One of the largest gaps was the paucity of research on integrating medical care into mental health care for patients with serious and persistent mental illness.

In February 2010, AHRQ commissioned the RTI International–University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) to work with stakeholders to develop a prioritized list of future research needs in this area that would inform researchers, funders, practitioners, advocacy groups, patients, and family members. A structured approach, including the AHRQ population, intervention, comparator, outcome, timeframe, setting (PICOTS) framework, to future research needs prioritization is new: this project therefore also served as a pilot for development and testing of methods to conduct such an evaluation. In the future, we anticipate that all AHRQ-sponsored comparative effectiveness research systematic reviews will contain a documentation of future research needs. In this report, we use the term “research gap” to indicate gaps from the report, the work with the stakeholders, and the RTI-UNC team review of the report; we used the identified gaps to generate “research needs,” including definitions of key study design issues such as PICOTS, and methods considerations such as feasibility and sample size.