# Appendixes

Appendix A Rationale for Final Prioritized List of Potential Research Studies (Detailing Rationale, PICOTS, and Study Design Considerations)

Appendix B Methods for Paying for Care Management (figure 13 from Bachman et al., 2006)

Appendix C Search Strategy for Ongoing Trials and Publications Since Release of the Original 2008 Report

Appendix D Ongoing Trials and Recent Publications

Appendix E Prioritization Tools

Appendix F AHRQ’s EHC Program Selection Criteria for New Research

Appendix G Levels of Integration Matrix (Developed from the Integration Matrix Outlined in figure 3 of the 2008 AHRQ Review)

Appendix H Interim Results from the First and Second Rounds of Prioritization with Stakeholders

Appendix I Analytic Framework (figure 1 from the 2008 AHRQ review)