# Analytic Framework (figure 1 from the 2008 AHRQ review2)

Characteristics of integration linked to process of care

This figure outlines an analytic framework for integrated care. The framework describes both the characteristics of care and the process of care. Characteristics of care include, systematic screening which is linked to the integration of providers through co-location, systematic communication methods, shared medical records and shared decision making. This in turn is linked to integrated care and proactive follow-up through the delivery of new services, standardizing followup, ensuring formal adherence and clinical monitoring with feedback and also through education. These characteristics of care are shown to be linked to the process of care as follows. Systematic screening identifies mental health problems, which is directly linked to the ability of primary care providers or primary care/mental health provider teams to be more aware of mental health problems, more comfortable treating mentally ill patients and more likely to adhere to evidence based guidelines. This in turn affects patients by providing improved access to care, reduces stigma, encourages patient engagement and adherence to care. Integrating providers is also shown to have a direct influence on providers and integrated care coupled with proactive followup is shown to directly affect patients.