# Interim Results from the First and Second Rounds of Prioritization with Stakeholders

Results of the initial prioritization exercise. Figure H-1 and Table H-1 present findings from the two priority-setting exercises. Figure H-1 presents results from the Likert scale exercise where stakeholders were asked to rank each of the 40 research gaps on a scale of 1–5 (1 being low priority for future research, 5 being high priority). Mean Likert scores for each gap along with the standard deviation are provided. Results suggest that all the identified gaps represent research needs since all were ranked as moderately or very important. All but one gap received a mean priority score greater than 3, with 58% scoring 4 or above. Effectiveness of integrated care for minor depression versus major depression (gap #19) received a mean Likert score of 2.9 ± 0.9, placing it at the bottom of the priority list. Studies examining effective models/strategies of integrated payment for integrated care (gap #31) topped the list as the highest research need, with a mean Likert score of 4.8 ± 0.44.

Figure H-1 Likert scale priority

Figure H-1 (Likert scale priority) presents results from the Likert scale exercise where stakeholders were asked to rank each of the 40 research gaps identified in the paper on a scale of 1 to 5, with 1 being low priority for future research and 5 being high priority. Mean Likert scores and standard deviations are provided for each gap. All research gaps were ranked as moderately or very important, a result that suggests that all identified gaps represent research needs.

Table H-1 Total for each of 40 research gaps

Research Gap | Total (out of a possible 45)
Effectiveness of cross-cutting models/strategies for integration of mental health into primary care | 16
A resource where researchers and policymakers can go to identify existing programs that already show return on investment related to different levels of integration. | 14
Cost-effectiveness of integrated models | 11
Studies examining effective models/strategies of integrated payment for integrated care | 10
Studies examining the use of information technology (IT) including telemedicine, text messaging, and use of the Internet | 10
Effectiveness and use of electronic medical records | 9
Effectiveness of the medical home as a model/strategy for integrated care | 8
Studies examining sustainability of integrated care independent of grant funding | 8
Studies examining the business case for integration | 8
Studies examining the translation/adaption/implementation of successful models/strategies in community settings | 8
Effective models/strategies of integration for severe mental illness | 7
Effective methods of integrating primary care into specialty mental health practice settings | 6
Effectiveness of current treatments and treatment combinations in relation to integrated care | 5
Effectiveness of integrated care for children and adolescents | 5
Effectiveness of integrated care on health disparities | 5
Effectiveness of measurement-based care for case identification, monitoring, and disease management | 5
Effectiveness of very brief psychotherapies that may be more readily delivered in primary care settings as part of an integrated treatment approach | 5
Studies identifying the various components of integrated care and determine the value added by each component individually and synergistically | 5
Effectiveness of integrated care for patients with dual Medicaid and Medicare eligibility | 4
Effectiveness of integrated care in rural settings | 3
Effectiveness of integrated care in the presence of comorbidities | 3
Studies examining integrated care for severe mental illness as a population of focus | 3
Effectiveness of integrated care and consistency with cultural values of various minority groups | 2
Effectiveness of integrated care for mental health on general medical | 2
Effectiveness of integration in community settings, particularly when addressing multiple mental health problems rather than single conditions (such as depression) | 2
Effective models/strategies of integration for alcohol abuse | 1
Effective models/strategies of integration for posttraumatic stress disorder | 1
Effectiveness of web-based psychotherapies in combination with primary care pharmacotherapy | 1
Studies assessing the populations most likely to benefit from integrated care | 1
Studies comparing integrated care to systematic practice (i.e., some variation of usual care) | 1
Studies examining the fidelity of integration principles (evidence-based intervention, communication among clinicians, followup) to what is delivered in integrated care | 1
Studies testing the comparative efficacy and effectiveness of explicit variations of integration | 1
Studies examining the generalizability of current integration models | 1
Effective models/strategies for bipolar disorder | 0
Effective models/strategies for postpartum depression | 0
Effective models/strategies of integration for anxiety disorder | 0
Effective models/strategies of integration for attention deficit hyperactivity disorder | 0
Effective models/strategies of integration for mood disorders | 0
Effective models/strategies of integration for somatization | 0
Effectiveness of integrated care for minor depression versus major depression | 0

Table H-1 presents results for the second exercise, which employed a “forced prioritization” method by providing each stakeholder with 20 “chits” to assign among 40 gaps, allowing a maximum of 5 chits to be allotted to any one gap. This method proved most effective, clearly showing a rank order of priority gaps for future research needs. The effectiveness of cross-cutting models/strategies across multiple mental health diagnostic categories, as opposed to a separate strategy for each diagnostic category, emerged as the top priority for future research among our stakeholders obtaining 16 of a possible 45 chits.

A resource for researchers and policymakers to identify existing programs that already show return on investment related to different levels of integration was identified as an important need by stakeholders. This gap is worthy of mention while recognizing that it is not an actual research topic and was not included in the second round of voting. Also of note is the fact that some of the initial 40 gaps could be combined under similar headings, changing the rank order of results. The second stakeholder call included a discussion of combining similar gaps as well as deleting those that ranked poorly as low-priority research needs; from this a refined, more focused list was developed for subsequent prioritization.

Results of the second prioritization exercise. The second prioritization exercise presented stakeholders with a nonranked list of 20 gaps and 12 chits, 4 of which could be assigned to any one gap. Stakeholders were asked to consider the 20 gaps and to prioritize what they considered to be the most important research needs for future study. The results are presented in Table H-2. Each gap could in theory have been awarded a maximum of 28 chits.

Table H-2 Results from the Second Prioritization Exercise

Research Need | Number of chits out of 28 (7 raters)
Effective methods of integrating primary care into specialty mental health practice settings. Studies could include effects on outcomes of both medical conditions (for example obesity, diabetes) as well as mental illness. | 10
Effectiveness of cross-cutting models/strategies for integration of mental health into primary care. “Cross-cutting” here indicates care across multiple mental health diagnostic categories, as opposed to a separate strategy for each diagnostic category, such as depression or anxiety disorder. | 10
Studies examining the use of information technology (IT) including text messaging, use of the Internet, and effective use of electronic medical records for integrated mental and general medical health care. These would focus on true interoperability and sharing of information between the primary care and the mental health professionals. | 10
Studies examining sustainability of integrated care without external support such as grant funding. Integrated care can be delivered with special grant funding but are there ways of supporting it following or in lieu of grant funding? | 9
Studies examining the translation/adaption/implementation of successful models/strategies in community settings. How can efficacious interventions be incorporated into everyday practice in the face of weak incentives and competing medical priorities? | 7
Studies examining effective models/strategies of integrated or “bundled” payment for integrated care. Are there effective ways of combining primary care reimbursement mechanisms with reimbursements for mental health care services? | 6
Studies identifying the effectiveness of various components of integrated care, determining the value added by each component individually and synergistically. What are the efficacious elements in integrated care? | 6
Cost effectiveness of integrated models from the societal perspective. | 5
Studies examining the business case for integration. When a practice or system invests in integrated care staffing and services, what are the revenues generated, and what are the effects on downstream costs such as hospitalization? Studies could take the perspective of the practice, the health care system, or the payer. | 5
Effectiveness of measurement-based integrated care for case identification, treatment, and monitoring, focusing on mental health conditions other than depression. | 4
Effectiveness of integrated care for patients with dual Medicaid and Medicare eligibility. | 3
Effectiveness of integrated care in the presence of both physical health comorbidities such as diabetes or chronic pain, as well as mental health comorbidities, such as the co-occurrence of depression and anxiety disorder. | 2
Effectiveness of the medical home as a model/strategy for integrated care. The “medical home” could be a primary care office for many patients, but could also be a specialty mental health practice with elements of primary care integrated to form the “home.” | 2
Effective models/strategies of integration for alcohol abuse. | 1
Effectiveness of current treatments and treatment combinations in relation to integrated care. For example, how does integrated care compare with, or function as an adjunct to, brief psychotherapeutic interventions delivered in a primary care office? | 1
Effectiveness of integrated care for children and adolescents. | 1
Effectiveness of integrated care on health disparities, including racial and ethnic disparities in care patterns and outcomes in mental health and medical outcomes | 1
Effectiveness of telemedicine as a model of integrated care for mental and general medical health care. | 1
Effectiveness of integrated care for mental health on general medical health, such as improvement in hemoglobin A1c among diabetics who are treated for depression in an integrated care system. | 0
Effectiveness of web-based psychotherapies in combination with primary care pharmacotherapy, when there is involvement of a mental health professional in the care. | 0