# Levels of Integration Matrix (Developed from the Integration Matrix Outlined in figure 3 of the 2008 AHRQ Review2)

Level of integrated process of care

| | Low level | Intermediate level | High level
Level of Integrated Providers | Low level | Example: Referral, no collaboration or reported communication between providers, separate locations, PCP directed | Example: Computer-generated reports or presentation of report by nurse/pharmacist to PCP, separate location, PCP directed | Example: Communication through electronic medical record recommendations and progress notes, face-to-face meetings with care manager, separate locations linked by telemedicine, PCP directed but team recommendations
Level of Integrated Providers | Intermediate level II | Example: Referral, communication through weekly consultation between PCP and MH provider, separate locations, PCP directed | Example: Referral, PCP and MH provider review cases weekly, medication changes communicated between providers, separate locations, decisionmaking coordinated between providers | Example: Cases identified through screening, both providers review cases weekly, formal communication between providers, co-located, PCP directed
Level of Integrated Providers | Intermediate level I | Example: Referral, communication through weekly consultation between PCP and MH provider, separate locations, MH provider directed | Example: Recruitment through screening, PCP receives consultation letter after each MH visit, psychiatrist directed | Example: Cases identified through referral and screening, care manager reviews cases weekly, formal and informal contact between providers, co-located, coordinated decisionmaking
Level of Integrated Providers | High level | Example: No case identification, regular case conferences between PCP and MH providers, co-located, consensus on decisionmaking | Example: Case identification through screening, treatment plan developed jointly between providers, co-located, joint decisionmaking in defined roles | Example: Cases identified through screening and referral, regular team meetings between providers (formal and informal), treatment plan consensus, co-located, joint decisionmaking and consensus

MH=mental health; PCP=primary care physician.