# Prioritization Tools

Online prioritization tool