# Ongoing Trials and Recent Publications

## Ongoing Trials

### Source: Clinical trials.gov

Baylor College of Medicine. Cognitive behavior treatment of older adults with generalized anxiety disorder in primary care. 2009. Accessed August 18, 2010. ]. Available at http://clinicaltrials.gov/ct2/show/NCT00765219.
Children’s Hospital of Philadelphia. Preventing youth suicide in primary care: a family model. 2004. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00604097.
Department of Veterans Affairs. Behavioral activation for Posttraumatic Stress Disorder (PTSD)/depression treatment in Operations Iraqi Freedom and Enduring Freedom (OIF/OEF) veterans. 2009. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00805532.
Department of Veterans Affairs. Telemedicine outreach for post traumatic stress in CBOCs (TOP). 2009. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00821678.
Department of Veterans Affairs. Implementing evidence-based mental health practices in primary care. 2010. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00996775.
HealthPartners Research Foundation RAND University of Washington, et al. Evaluation of a natural experiment to improve statewide depression care in MN (DIAMOND). 2008. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00781703.
Johns Hopkins University, Leonard & Helen R. Stulman Charitable Foundation. Case management study for postpartum depression and intimate partner violence. 2008. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00560027.
Massachusetts General Hospital. Effectiveness of telepsychiatry-based culturally sensitive collaborative treatment of depressed Chinese Americans. 2009. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00854542.
National Institute of Mental Health (NIMH). Effectiveness of collaborative depression care management in treating depressed low-income Hispanics with diabetes. 2005. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00709150.
National Institute of Mental Health (NIMH). Effectiveness of collaborative services in primary care for treating children with behavior disorders (SKIP). 2007. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00600470.
National Institute of Mental Health (NIMH). Effectiveness of a technology assisted behavioral intervention in assisting people with major depressive disorder. 2009. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00719979.
National Institute of Mental Health (NIMH). Feasibility of depression care management by e-mail. 2009. Accessed August 18, 2010. ]. Available at http://clinicaltrials.gov/ct2/show/NCT00755235.
National Institute of Mental Health (NIMH). Treatment for depressed primary care patients. 2009. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT01014312.
National Library of Medicine (US). Assessing different methods of anxiety care in pediatric settings. 2008. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00769925.
Robert Wood Johnson Foundation, National Institute of Mental Health (NIMH), William T. Grant Foundation (WTGF). Clinical and cost effectiveness of brief cognitive-behavioral therapy (CBT) for pediatric internalizing disorders. 2004. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00669526.
Seattle Children’s Hospital. Children’s Attention Deficit Disorder with Hyperactivity (ADHD) Telemental Health Treatment Study (CATTS). 2009. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/record/NCT00830700.
South Central VA Mental Illness Research, Education & Clinical Center. Facilitating implementation of cognitive behavioral therapy in primary care and community clinics. 2008. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00854542.
University of Washington HRSA/Maternal and Child Health Bureau. Adolescent Trauma Recovery and Stress Disorders Collaborative Care (ATRSCC) Model Program Trial. 2008. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00619255.
Weill Medical College of Cornell University, National Institute of Mental Health (NIMH), New York State Psychiatric Institute et al. Pilot study of shared care of ADHD in a pediatric clinic: colocation of a psychologist as an ADHD care manager (shared care). 2006. Accessed August 18, 2010. Available at http://clinicaltrials.gov/ct2/show/NCT00644566.

### Source: NIH-RePORTER

University of Pennsylvania. Adherence to antidepressant medication and hypertension treatment. 2009. Accessed August 18, 2010. Available at http://projectreporter.nih.gov/project_info_details.cfm?aid=7790809&icde=5006590.
Emory University. Improving primary care of patients with mental disorders (2R01MH070437-06A1). 2004. Accessed August 18, 2010. Available at http://projectreporter.nih.gov/project_info_details.cfm?aid=7786345&icde=5023022.
University of Massachusetts, Medical School–Worcester. Indianapolis interventions and practice research infrastructure program. 2008. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7812208&icde=5120573.
Indiana University–Purdue University at Indianapolis. Integrated Care Model for Homeless Mothers (ICMHM). 2009. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7788054&icde=5120621.
University of California, San Francisco. Integrated drug and medical care cost and effectiveness. 2009. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7794859&icde=5120945.
University of Washington. A randomized trial in liaison psychiatry in primary care 1987. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7898568&icde=5120995.
Duke University. Integrated treatment of persons with co-occurring HCV and alcohol use/abuse. 2008. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7687970&icde=5121032.
Seattle Children’s Hospital. Adolescent collaborative care treatment for depression. 2009. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7919256&icde=5121045.
Kaiser Foundation Research Institute. Brief, primary care CBT for unmedicated depressed youth. 2006. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7805537&icde=5121064.
University of Arkansas. MED SCIS LTL ROCK. CALM: improving primary care anxiety outcomes. 2005. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7631258&icde=5121091.
University of Pittsburgh at Pittsburgh. Collaborative mental health services for behavior disorders in primary care. 2000. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7768423&icde=5121111.
Oregon Health and Science University. Developing an abuse-sensitive depression care model. 2005. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7538402&icde=5121255.
University of Washington. Early combined intervention after traumatic injury. 2005. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7686287&icde=5121277.
Northwestern University. Effect of chronic illness complexity on evidence-based depression treatment. 2008. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7680208&icde=5121304.
University of Pittsburgh at Pittsburgh. Identification and therapy of postpartum depression. 2006. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7902176&icde=5121559.
University of Southern California. Multifaceted depression diabetes program for Hispanics. 2005. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7342771&icde=5121819.
University of Arkansas MED SCIS LTL ROCK. Telemedicine outreach for post-traumatic stress in community-based outpatient clinics (CBOCs). 2006. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7884398&icde=5121835.
Seattle Children’s Hospital. Telemental health to improve mental health care and outcomes for children in underserved areas. 2008. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7872838&icde=5121853.
Massachusetts General Hospital. Telepsychiatry and culturally sensitive treatment of depressed Asian Americans. 2008. Accessed August 18, 2010. Available at http://www.projectreporter.nih.gov/project_info_description.cfm?aid=7890385&icde=5121871.

## Ongoing Trials Presented to Stakeholders for the First Conference Call

Key Question | Research gaps | Ongoing Studies that may address gaps (N=41)
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | Population; A Models of integration for anxiety disorder | [underlined: Population: A] NCT00765219 NCT00769925 NCT00669526 U01MH070022-01A2
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | B Models of integration for Somatization | [underlined: Population: B]
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | C Models of integration for alcohol abuse | [underlined: Population: C] NCT00996775 NCT00619255
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | D Models of integration for ADHD | [underlined: Population: D] NCT00830700 NCT00644566 NCT00600470 R01MH063272-06A1
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | E Models of integration for PTSD | [underlined: Population: E] NCT00974402 R01MH073613-04
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | F Models of integration for severe mental illness | [underlined: Population: F] 2R01MH070437-06A1
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | G Models of integration for mood disorders | [underlined: Population: G]
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | H Models of integration for postpartum depression | [underlined: Population: H]
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | I Models on integration for bipolar disorder | [underlined: Population: I]
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | J Models of integration (cross-cutting) | [underlined: Population: J]
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | Intervention/Comparator
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | A Studies testing explicit variations of integration | [underlined: Intervention/Comparator: A] NCT00676962
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | B Studies examining the fidelity of integration principles (evidence-based intervention, communication among clinicians, followup) to what is delivered | [underlined: Intervention/Comparator: B] 5R37DA010572-14
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | C Methods of integrating primary care into specialty mental health | [underlined: Intervention/Comparator: C]
1. What models of integration have been used? What is the evidence that integrated care leads to better outcomes | D Studies comparing integrated care to systematic practice (i.e. some variation of usual care) | [underlined: Intervention/Comparator: D]
2. To what extent does the impact of integrated care programs on outcomes vary for different populations? | Population; A Populations most likely to benefit from this type of integrated care | [underlined: Population: A] NCT00765219 NCT00854542 NCT00805532 NCT01014312 NCT00560027 1R34MH085881-01A1 K23MH073008-01
2. To what extent does the impact of integrated care programs on outcomes vary for different populations? | B Integrated care for children and adolescents | [underlined: Population: B] NCT00560027 NCT00769925 NCT00669526 NCT00830700 NCT00644566 NCT00619255 NCT00600470 NCT006040971 1R01MH085645-01A1 ROIMH073918-01A1 R01MH063272-06A1 R01MH081997-01A1
2. To what extent does the impact of integrated care programs on outcomes vary for different populations? | C Integrated care and consistency with cultural values of various minority groups | [underlined: Population: C] NCT00854542 NCT00709150 NCT00570427 U01MH070022-01A2 R01MH068468-01A2 R01MH079831-01A2
2. To what extent does the impact of integrated care programs on outcomes vary for different populations? | D Effects of integrated care on health disparities | [underlined: Population: D]
2. To what extent does the impact of integrated care programs on outcomes vary for different populations? | E Effects of integrated care in the presence of comorbidities | [underlined: Population: E] NCT00805532 NCT00709150 1R34MH085880-01A1 5R24MH080827-02 2R01MH070437-06A1 5R01MH041739-20 5R21AA017252-02 IIR06-082 K23MH073008-01 R01MH073613-04 R21HS017635-01 R01MH068468-01A2
2. To what extent does the impact of integrated care programs on outcomes vary for different populations? | F Effects of integrated care for minor depression versus major depression | [underlined: Population: F]
2. To what extent does the impact of integrated care programs on outcomes vary for different populations? | Setting; A Integrated care in rural settings | [underlined: Setting: A] MHI08-098 R01MH081997-01A1
3. What are the identified barriers to successful integration and sustainability? | Population; A Studies which examine generalizability of current models
3. What are the identified barriers to successful integration and sustainability? | Intervention/Comparator; A Models of integrated payment
3. What are the identified barriers to successful integration and sustainability? | Outcomes; A Studies examining sustainability | [underlined: Outcomes:A] NCT00676962
4. To what extent did successful integration programs make use of health information technology? | Intervention/Outcomes; A Use of information technology (IT) in integrated care | [underlined: Intervention/Outcomes: A] NCT00830700 NCT00719979 NCT00755235 NCT00821678 NCT00854542 R01MH071825-01A2 NCT00996775 5R24MH080827-02 MHI08-098 R01MH081997-01A1 R01MH079831-01A2
5. What financial and/or reimbursement structure was employed in successful integration programs? Is any specific financial/reimbursement strategy superior to another? | Intervention/comparator; A Studies examining the business case for integration; B Cost-effectiveness of integrated models | [underlined: Intervention/Comparator: A] NCT00781703 2R01MH070437-06A1 NCT00669526 5R37DA010572-14 ROIMH073918-01A1 U01MH070022-01A2
6. What are the key elements of programs that have been successfully implemented and sustained in large health systems? | Intervention; A Studies investigating the vital elements of successful integration | [underlined: Intervention: A] NCT00676962

## Relevant Publications Since the 2008 AHRQ Review

1 Alexopoulos GS, Reynolds CF 3rd, Bruce ML, et al. Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. A J Psychiatry. Aug. 2009;166(8):882-890.
2 Arean PA, Ayalon L, Jin C, et al. Integrated specialty mental health care among older minorities improves access but not outcomes: results of the PRISMe study. Int J Geriatr Psychiat. 2008;23(10):1086-1092.
3 Arean PA, Gum AM, Tang L, et al. Service use and outcomes among elderly persons with low incomes being treated for depression. Psychiatr Serv. Aug. 2007;58(8):1057-1064. [pmid: 17664516].
4 Ayalon L, Arean PA, Linkins K, et al. Integration of mental health services into primary care overcomes ethnic disparities in access to mental health services between black and white elderly. Am J Geriatr Psychiatry. Oct. 2007;15(10):906-912. [pmid: 17911367].
5 Babor TF, McRee BG, Kassebaum PA, et al. Screening, Brief Intervention, and Referral to Treatment (SBIRT): toward a public health approach to the management of substance abuse. Subst Abus. 2007;28(3):7-30. [pmid: 18077300].
6 Bao Y, Post EP, Ten Have TR, et al. Achieving effective antidepressant pharmacotherapy in primary care: The role of depression care management in treating late-life depression. J Am Geriatr Soc. 2009;57(5):895-900. [pmid: 19484846].
7 Barry KJ. Collective inquiry: understanding the essence of best practice construction in mental health. J Psychiatr Ment Health Nurs. Sep. 2007;14(6):558-565. [pmid: 17718728].
8 Bauer MS, Biswas K, Kilbourne AM. Enhancing multiyear guideline concordance for bipolar disorder through collaborative care. A J Psychiatry. Nov. 2009;166(11):1244-1250.
9 Begley CE, Hickey JS, Ostermeyer B, et al. Integrating behavioral health and primary care: the Harris County Community Behavioral Health Program. Psychiatr Serv. Apr. 2008;59(4):356-358. [pmid: 18378830].
10 Bogner HR, de Vries HF. Integration of depression and hypertension treatment: a pilot, randomized controlled trial. Ann Fam Med. Jul–Aug. 2008;6(4):295-301. [pmid: 18626028].
11 Chan D. Depression and comorbid PTSD in veterans: Evaluation of collaborative care programs and impact on utilization and costs. Dissertation Abstr Int: Sect B: The Sciences and Engineering. 2008;68(12-B):7922.
12 Chang-Quan H, Bi-Rong D, Zhen-Chan L, et al. Collaborative care interventions for depression in the elderly: a systematic review of randomized controlled trials. J Investig Med. Feb. 2009;57(2):446-455.
13 Chavira DA, Stein MB, Golinelli D, et al. Predictors of clinical improvement in a randomized effectiveness trial for primary care patients with panic disorder. J Nerv Ment Dis. Oct. 2009;197(10):715-721. [pmid: 19829198].
14 Christensen H, Griffiths KM, Gulliver A, et al. Models in the delivery of depression care: a systematic review of randomised and controlled intervention trials. BMC Fam Pract. 2008;9:25. [pmid: 18454878].
15 Coffey CE. Health issues in the Arab American community. Integrating mental and general medical health care—the Henry Ford health system experience. Ethn Dis. Summer. 2007;17(2 Suppl 3):S362-S3.
16 Costantino G, Malgady RG, Primavera LH. Congruence between culturally competent treatment and cultural needs of older Latinos. J Consult Clin Psychol. Oct. 2009;77(5):941-949. [pmid: 19803573].
17 Craske MG, Roy-Byrne PP, Stein MB, et al. Treatment for anxiety disorders: Efficacy to effectiveness to implementation. Behav Res Ther. Nov. 2009;47(11):931-937. [pmid: 19632667].
18 Ell K, Quon B, Quinn DI, et al. Improving treatment of depression among low-income patients with cancer: the design of the ADAPt-C study. Gen Hosp Psychiatry. May–Jun. 2007;29(3):223-231. [pmid: 17484939].
19 Ell K, Xie B, Quon B, et al. Randomized controlled trial of collaborative care management of depression among low-income patients with cancer. J Clin Oncol. Sep 20. 2008;26(27):4488-4496. [pmid: 18802161].
20 Epstein JN, Rabiner D, Johnson DE, et al. Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Arch Pediatr Adolesc Med. Sep. 2007;161(9):835-840. [pmid: 17768282].
21 Fann JR, Fan MY, Unutzer J. Improving primary care for older adults with cancer and depression. J Gen Intern Med. Nov. 2009;24(Suppl 2):S417-24. [pmid: 19838842].
22 Fletcher J, Bower PJ, Gilbody S, et al. Collaborative care for depression and anxiety problems in primary care. Cochrane Database Syst Rev. 2007(2).
23 Ford DE. Optimizing outcomes for patients with depression and chronic medical illnesses. Am J Med. Nov. 2008;121(11 Suppl 2):S38-S44. [pmid: 18954591].
24 Fortney JC, Pyne JM, Edlund MJ, et al. A randomized trial of telemedicine-based collaborative care for depression. J Gen Intern Med. Aug. 2007;22(8):1086-1093. [pmid: 17492326].
25 Funderburk JS, Maisto SA, Sugarman DE, et al. How do alcohol brief interventions fit with models of integrated primary care?. Fam Syst Health: J Collaborat Fam HealthC. 2008;26(1):1-15.
26 Gardenier D, Neushotz LA, O’Connor-Moore N. Medical/psychiatric comanagement by nurse practitioners in chronic hepatitis C treatment: a case study. Arch Psychiatr Nurs. Apr. 2007;21(2):87-90. [pmid: 17397690].
27 Gjerdingen D, Katon W, Rich DE. Stepped care treatment of postpartum depression: a primary care-based management model. Womens Health Issues. Jan–Feb. 2008;18(1):44-52. [pmid: 18215764].
28 Goossen RB, Staley JD, Pearson M. Does the introduction of shared care therapists in primary health care impact clients’ mental health symptoms and functioning?. Can J Comm Mental Health. 2008;27(2):37-46.
29 Guevara JP, Greenbaum PE, Shera D, et al. Survey of mental health consultation and referral among primary care pediatricians. Acad Pediatr. Mar–Apr. 2009;9(2):123-127. [pmid: 19329104].
30 Harkness EF, Bower PJ. On-site mental health workers delivering psychological therapy and psychosocial interventions to patients in primary care: effects on the professional practice of primary care providers. Cochrane Database Syst Rev. 2009;1:CD000532. [pmid: 19160181].
31 Henke RM, McGuire TG, Zaslavsky AM, et al. Clinician- and organization-level factors in the adoption of evidence-based care for depression in primary care. Health Care Manage Rev. Oct–Dec. 2008;33(4):289-299. [pmid: 18815494].
32 Hine CE, Howell HB, Yonkers KA. Integration of medical and psychological treatment within the primary health care setting. Soc Work Health Care. 2008;47(2):122-134. [pmid: 18956504].
33 Holtrop JS, Dosh SA, Torres T, et al. The community health educator referral liaison (CHERL): a primary care practice role for promoting healthy behaviors. Am J Prev Med. Nov. 2008;35(5 Suppl):S365-S372. [pmid: 18929983].
34 Huang CQ, Dong BR, Lu ZC, et al. Collaborative care interventions for depression in the elderly: a systematic review of randomized controlled trials (Structured abstract). J Investigat Med. 2009(2):446-455.
35 Katon WJ, Russo JE, Von Korff M, et al. Long-term effects on medical costs of improving depression outcomes in patients with depression and diabetes. Diabetes Care. Jun. 2008;31(6):1155-1159. [pmid: 18332158].
36 Katon WJ, Seelig M. Population-based care of depression: team care approaches to improving outcomes. J Occup Environ Med. Apr. 2008;50(4):459-467. [pmid: 18404019].
37 Kira I, Hammad A, Abou-Mediene S. Health issues in the Arab American community. Models of health and mental health integration: ACCESS Community Health and Research Center model. Ethn Dis. Summer. 2007;17(2 Suppl 3):S366-S369.
38 Konig HH, Born A, Heider D, et al. Cost-effectiveness of a primary care model for anxiety disorders. Br J Psychiatry. Oct. 2009;195(4):308-317. [pmid: 19794198].
39 Kroenke K, Shen J, Oxman TE, et al. Impact of pain on the outcomes of depression treatment: results from the RESPECT trial. Pain. Jan. 2008;134(1–2):209-215. [pmid: 18022319].
40 Lee HS, Mericle AA, Ayalon L, et al. Harm reduction among at-risk elderly drinkers: a site-specific analysis from the multi-site Primary Care Research in Substance Abuse and Mental Health for Elderly (PRISM-E) study. Int J Geriatr Psychiatr. 2009;24(1):54-60.
41 Lee PW, Dietrich AJ, Oxman TE, et al. Sustainable impact of a primary care depression intervention. J Am Board Fam Med. Sep–Oct. 2007;20(5):427-433. [pmid: 17823459].
42 Manoleas P. Integrated primary care and behavioral health services for Latinos: a blueprint and research agenda. Soc Work Health Care. 2008;47(4):438-454. [pmid: 19042495].
43 Mavandadi S, Ten Have TR, Katz IR, et al. Effect of depression treatment on depressive symptoms in older adulthood: the moderating role of pain. J Am Geriatr Soc. Feb. 2007;55(2):202-211. [pmid: 17302656].
44 McGuire J, Gelberg L, Blue-Howells J, et al. Access to primary care for homeless veterans with serious mental illness or substance abuse: a follow-up evaluation of co-located primary care and homeless social services. Adm Policy Ment Health. Jul. 2009;36(4):255-264. [pmid: 19280333].
45 Milam-Miller S. The psychiatrist as consultant: working within schools, the courts, and primary care to promote children’s mental health. Psychiatr Clin North Am. Mar. 2009;32(1):165-176. [pmid: 19248923].
46 Neufeld JD, Yellowlees PM, Hilty DM, et al. The e-Mental Health Consultation Service: providing enhanced primary-care mental health services through telemedicine. Psychosomatics. Mar–Apr. 2007;48(2):135-141. [pmid: 17329607].
47 Parker AG, Hetrick SE, Purcell R, et al. Consultation liaison in primary practice for mental health problems. Cochrane Database Syst Rev. 2008(2).
48 Pomerantz A, Cole BH, Watts BV, et al. Improving efficiency and access to mental health care: combining integrated care and advanced access. Gen Hosp Psychiatry. Nov–Dec. 2008;30(6):546-551. [pmid: 19061681].
49 Post EP, Van Stone WW. Veterans Health Administration primary care-mental health integration initiative N C Med J. Jan–Feb. 2008;69(1):49-52.
50 Robinson PJ, Strosahl KD. Behavioral health consultation and primary care: lessons learned. J Clin Psychol Med Settings. Mar. 2009;16(1):58-71. [pmid: 19184376].
51 Rollman BL, Belnap BH, LeMenager MS, et al. Telephone-delivered collaborative care for treating post-CABG depression: a randomized controlled trial. J Am Med Assoc. Nov 18. 2009;302(19):2095-2103.
52 Schutte K, Yano EM, Kilbourne AM, et al. Organizational contexts of primary care approaches for managing problem drinking. J Subst Abuse Treat. Jun. 2009;36(4):435-445. [pmid: 19004595].
53 Simon G. Collaborative care for mood disorders. Curr Opin Psychiatry. Jan. 2009;22(1):37-41. [pmid: 19122533].
54 Skultety KM, Rodriguez RL. Treating geriatric depression in primary care. Curr Psychiatry Rep. Feb. 2008;10(1):44-50. [pmid: 18269894].
55 Smith SM, Allwright S, O’Dowd T. Effectiveness of shared care across the interface between primary and specialty care in chronic disease management. Cochrane Database Syst Rev. 2007;3:CD004910. [pmid: 17636778].
56 Smolders M, Laurant M, Roberge P, et al. Knowledge transfer and improvement of primary and ambulatory care for patients with anxiety. Can J Psychiatry. May. 2008;53(5):277-293. [pmid: 18551849].
57 Thielke SM, Fan MY, Sullivan M, et al. Pain limits the effectiveness of collaborative care for depression. Am J Geriatr Psychiatry. Aug. 2007;15(8):699-707. [pmid: 17670998].
58 Unutzer J, Katon WJ, Fan MY, et al. Long-term cost effects of collaborative care for late-life depression. Am J Manag Care. Feb. 2008;14(2):95-100. [pmid: 18269305].
59 Van Leeuwen Williams E, Unutzer J, Lee S, et al. Collaborative depression care for the old-old: findings from the IMPACT trial. Am J Geriatr Psychiatry. Dec. 2009;17(12):1040-1049. [pmid: 19934666].
60 Vannoy SD, Arean P, Unutzer J. Advantages of using estimated depression-free days for evaluating treatment efficacy. Psychiatr Serv. Feb. 2010;61(2):160-163. [pmid: 20123821].
61 Voils CI, Olsen MK, Williams JW, et al. Identifying Depressed Older Adults in Primary Care: A Secondary Analysis of a Multisite Randomized Controlled Trial. Prim Care Companion J Clin Psychiatry. 2008;10(1):9-14. [pmid: 18311416].
62 Walker J, Sharpe M. Depression Care for People with Cancer: a collaborative care intervention. Gen Hosp Psychiatry. Sep–Oct. 2009;31(5):436-441. [pmid: 19703637].
63 Watts BV, Shiner B, Pomerantz A, et al. Outcomes of a quality improvement project integrating mental health into primary care. Qual Saf Health Care. Oct. 2007;16(5):378-381. [pmid: 17913780].
64 Weaver MR, Conover CJ, Proescholdbell RJ, et al. Cost-effectiveness analysis of integrated care for people with HIV, chronic mental illness and substance abuse disorders. J Ment Health Policy Econ. Mar. 2009;12(1):33-46. [pmid: 19346565].
65 Williams JW Jr. Managed depression care reduces mortality in older adults with major depression. Evidence Based Mental Health. 2008;11(1).
66 Wood SA, Austin SA. Building bridges in Bridgeport for HIV-positive substance abusers. J HIV/AIDS Soc Serv. 2009;8(1):20-34.
67 Zaller N, Gillani FS, Rich JD. A model of integrated primary care for HIV-positive patients with underlying substance use and mental illness. AIDS Care. Oct. 2007;19(9):1128-1133. [pmid: 18058396].
68 Zanjani F, Mavandadi S, TenHave T, et al. Longitudinal course of substance treatment benefits in older male veteran at-risk drinkers. J Gerontol A Biol Sci Med Sci. Jan. 2008;63(1):98-106. [pmid: 18245767].
69 Zeiss AM, Karlin BE. Integrating mental health and primary care services in the Department of Veterans Affairs health care system. J Clin Psychol Med Settings. Mar. 2008;15(1):73-78. [pmid: 19104957].