# Search Strategy for Ongoing Trials and Publications Since Release of the Original 2008 Report

Search for new publications. We began by updating the search strategy recorded in the original AHRQ review. This was translated from OVID-Medline to PubMed. We created an EndNote library with the main literature search topic—the intersection of integrated health care, primary health care concepts, and mental health concepts—to determine how many of the 61 references selected by the authors of the 2008 review were retrieved with the converted strategy. It should be noted that the investigators manually searched the references of all systematic reviews, which we did not replicate. The converted search was performed on February 7, 2010, in PubMed with the following results:

The total for the main topic (the intersection of integrated health care, primary health care concepts, and mental health/disorder concepts) (“Main Topic”): 6,863 references

a. Main Topic, limited to quantitative study types: 2,744
b. Main Topic, limited to qualitative study types: 223
c. Main Topic, limited to quantitative study types, and English language: 2,500
d. Main Topic, limited to qualitative study types, and English language: 213
e. Main Topic (6,852), limited to English language: 6,085
f. Main Topic, limited to “systematic reviews” subset in PubMed, OR Review publication type: 1,099
g. Main Topic, NOT one of the qualitative or quantitative study types searched above (“The Rest”): 3,469

These 3,469 remainder articles (g) were combined with sets c, d, and f, and duplicates removed, for a grand total of 6,085.

When limited to publication dates from October 2007 to the present, the totals were:

h Main Topic, limited to quantitative study types, English language, and publication date limit: 510
i Main Topic, limited to qualitative study types, English language, and publication date limit: 70
j Main Topic, limited to “systematic reviews” subset in PubMed, OR Review publication type, and publication date limit: 210
k Main Topic, NOT one of the qualitative or quantitative study types searched above (“The Rest”), and publication date limit: 488

Results in sets h, i, j, and k were combined for a total of 1,030 citations. We remodeled the search to take advantage of appropriate MeSH and minimize the use of keywords. This should result in a lower-yield and more targeted search. The converted search, using MeSH when available, was performed on February 4, 2010, with the following results:

The total for the main topic (the intersection of integrated health care, primary health care concepts, and mental health concepts) (Main Topic): 3,387 references

a. Main Topic, limited to quantitative study types: 983
b. Main Topic, limited to qualitative study types: 428
c. Main Topic, limited to quantitative study types, and English language: 935
d. Main Topic, limited to qualitative study types, and English language: 409
e. Main Topic (3,387), limited to English language: 3,101
f. Main Topic, limited to “systematic reviews” subset in PubMed, OR review publication type, and English language: 501
g. Main Topic, English language, NOT one of the qualitative or quantitative study types searched above (“The Rest”): 1,945
h. Main Topic, limited to quantitative study types, English language, and published 2007-present: 272
i. Main Topic, limited to qualitative study types, English language, and published 2007-present: 154
j. Main Topic, limited to “systematic reviews” subset in PubMed, OR review publication type, English language, and published 2007-present: 137
k. Main Topic, English language, NOT one of the qualitative or quantitative study types searched above (“The Rest”), and published 2007-present: 298

Results from e (Main Topic, limited to English language) were rerun in PubMed on February 8, 2010, and the results increased by two citations for a total of 3,103.

Results from h, i, j, and k were combined and duplicates removed, for a grand total of 652.

Analogous searches were run in the following databases with the following results:

- CINAHL = 276 retrieved, 165 added unique citations
- PsycINFO = 149 retrieved, 87 added unique citations
- Cochrane Library = 130 retrieved, 38 added unique citations

These additional searches contributed 290 new citations, for a new total in of 942 citations.

The translated search (1,030 citations) was initially imported into the new search (652) and duplicates (overlap) removed. There were 675 overlapping citations, leaving 297 that were identified by the new search but not by the old one, for a combined total of 1,327. We concluded that substantial activity has taken place since the publication of the AHRQ review in 2008. Although we did screen the titles and abstracts for relevance to the future research needs gap areas with dual review, we did not perform article abstraction nor did we perform quality assessment, since those activities would have represented a full update of the 2008 AHRQ review and were beyond the scope of this report.

Search for ongoing trials.

Clinical Trials.gov, searched February 8, 2010: ((“integrated care” OR “Cooperative Behavior” OR “Case Management” OR “Disease Management” OR consultation) AND (“Primary Health Care” OR “primary care”) AND (mental disorder* OR “Mental Health” OR Psychiatry OR Depression OR “Depressive Disorder”)). Limited to studies received between October 2007 to the present:

80 results

HSRProj, searched February 8, 2010: search same as ClinicalTrials.gov, limited to ongoing projects:

27 projects

NIH Research Portfolio (RePORTER)

Searched: “integrated care,primary care,mental” OR “integrated care,primary health care,mental” limited to active projects, 2010, 2009:

4 results

Searched: “integrated health care,primary health care,mental” limited to active projects, 2010, 2009:

1 result