# Rationale for Final Prioritized List of Potential Research Studies (Detailing Rationale, PICOTS, and Study Design Considerations)

## Research Need #1 What are effective methods of integrating primary care into specialty mental health practice settings? Studies would include both the mental and general health outcome(s) (e.g., obesity and depression)

Rationale. This research need was nominated by our stakeholders and also proposed in the 2008 AHRQ review2 conducted by the Minnesota EPC, which had found few studies addressing integration of primary care into the specialty mental health setting. Our literature scan in the first months of our project also found few such studies published since 2008. The burden of general medical illness in people with serious mental illness is substantial. People with serious mental illness are at greater risk for hypertension, diabetes with complications, hepatitis C, fluid/electrolyte disorders, obesity and early mortality related to cardiovascular disease, and nicotine abuse/dependence. They are also less likely to utilize indicated preventive interventions. Patients with serious mental illness may have difficulty accessing primary care.3

## Research Need #2 Effectiveness of cross-cutting models/strategies for integration of mental health into primary care. “Cross-cutting” here indicates care across multiple mental health diagnostic categories, as opposed to a separate strategy for each diagnostic category, such as depression or anxiety disorder

Rationale. The 2008 AHRQ report indicated that most of the evidence regarding integrated care had examined treatment of patients with depressive disorders in primary care. Diagnostic and treatment strategies evaluated in the 2008 report were often quite specific to depressive disorders. Other common mental health conditions, such as anxiety disorder, problem drinking, and somatization disorder have been much less studied. The stakeholder group felt that interventions requiring separate therapists or care managers for each of the common mental health disorders seen in primary care would likely be both administratively and financially unfeasible. An alternative strategy would be for the same personnel (M.S.W., Ph.D. psychologist, M.D. psychiatrist, care managers) to treat multiple conditions. Where available, specific evidence-based treatments would be tailored to specific conditions but a common approach would allow for treatment of patients who have more than one mental health diagnosis, such as anxiety and depression. In addition, the practice could gain efficiency through use of common processes for screening, case identification, communication with the mental health professionals, etc. Note that there is a connection between this question and research question #10 on measurement-based care. Valid and brief measures are needed for case identification and assessment of progress for each condition. The components of the cross-cutting strategies would also relate to research question #7 on the utility of components of integrated care.

## Research Need #3 Studies examining the use of information technology (IT) including text messaging, use of the Internet, and effective use of electronic medical records for integrated mental and general medical health care. These would focus on true interoperability and sharing of information between the primary care and the mental health professionals

Rationale. Our literature scan identified a number of ongoing studies, including the following, using various forms of health information technology in integrated care for mental health problems.

- Telemental Health to Improve Mental Health Care and Outcomes for Children in Underserved Areas14
- Effectiveness of a Technology-Assisted Behavioral Intervention in Assisting People With Major Depressive Disorder. Integrated Telemental Health Intervention for Depression in Primary Care15
- Feasibility of Depression Care Management by Email. Pilot Trial of Depression Care Management by Electronic Secure Messaging16
- Telemedicine Outreach for Post Traumatic Stress in CBOCs (TOP)17
- Effectiveness of Telepsychiatry-based Culturally Sensitive Collaborative Treatment of Depressed Chinese Americans18
- Adapting and testing telephone-based depression care management intervention for adolescent mothers19

The health IT area is rapidly progressing due to enhancements in technology and, especially, Office of the National Coordinator (ONC) initiatives providing substantial financial incentives for providers to install electronic health records and use them to care for patients through “meaningful use.” IT provides an opportunity for integrated care initiatives. This research need is specific to the use of IT as part of integrated care. Interventions by primary care or mental health providers to give IT support to patients through technology would not be considered in this area unless the mental health provider were providing the IT support linked and integrated with the primary care practice. This research question is related to research question #13, which examines the role of the medical home as a model for integrated care. Many medical home models make extensive use of health IT.

## Research Need #4 Studies examining sustainability of integrated care without external support such as grant funding. Integrated care can be delivered with special grant funding but are there ways of supporting it following or in lieu of grant funding?

Rationale. This question is related to research question # 9 on the “business case for integration,” but the study designs and analyses involved may be quite different. Are health care systems willing to support integrated care systems without grant support? What are the characteristics of the integrated care systems that are self-supporting? What are the characteristics of the health care systems that support them? By identifying the characteristics associated with self-sustaining, high-quality integrated care organizations, such efforts may be used to replicate successful integrated care organizations. What distinguishes this question from the purely financial “business case” question is the recognition that some organizations may value integrated care in mental health sufficiently to support such care even when the business case is not positive. Similarly, some organizations will likely not value integration even when a business case exists.

## Research Need #5 Studies examining the dissemination of successful models/strategies into community settings. How can efficacious interventions be incorporated into everyday practice in the face of weak incentives and competing medical priorities?

Rationale. A critical issue in moving from treatment efficacy to treatment effectiveness is whether the intervention can be applied to the average patient in the average practice. This is a particular issue for integrated care since there may be special challenges in implementing integrated care in many types of practices, such as smaller or more rural practices. Much of the literature has been conducted in larger practices, often in urban areas, or in well-developed health care systems such as the Veteran’s Administration or large HMOs. Integrated care practices may need to be adapted for these other settings, and research is needed to determine the fidelity and effectiveness of these adaptations.

## Research Need #6 Studies examining effective models/strategies of integrated or “bundled” payment for integrated care. Are there effective ways of combining primary care reimbursement mechanisms with reimbursements for mental health care services?

Rationale. According to the 2008 AHRQ report, no reimbursement system has been subjected to experiment so no evidence exists as to which reimbursement system may most effectively support integrated care. However, the recent Affordable Care Act (ACA) will generate multiple policy initiatives involving payment “bundling,” and it encouraged the Centers for Medicare and Medicaid Services to conduct demonstrations as to whether care could be delivered at lower cost with the same improved quality through combined payment across services or over time. Currently, the mechanisms of payment for mental health care are generally fee-for-service, so such bundling would be a significant change for both primary care and mental health practices and practitioners. Policymakers sometimes discuss such payment bundling as one component in the development of “accountable care organizations” (ACOs).

## Research Need #7 Studies identifying the effectiveness of various components of integrated care, and determining the value added by each component individually and synergistically. What are the efficacious elements of integrated care?

Rationale. By definition, integration strategies include multiple components and while integration at large appears to show positive results for symptom severity, treatment response, and remission when compared to usual care, the key elements required for a successful integration program remain elusive. The 2008 AHRQ report found no discernable effect of integration level, processes of care, or combination, on patient outcomes from mental health services in primary care settings. Moreover, on the basis of current evidence, it is not possible to distinguish the effects of increased attention to mental health problems from the effects of specific intervention strategies. This situation calls for studies that assess the efficacy and effectiveness of individual integration components as well as “packages” of components. Systematic dismantling of successful multi-component interventions would help to isolate efficacious elements. If some components are more expensive or administratively cumbersome to implement, but not essential to the effectiveness of integrated care interventions, then dissemination of integrated care could be simpler and more streamlined.

## Research Need #8 Cost-effectiveness of integrated models from the societal perspective

Rationale. The cost-effectiveness of integrated mental and general health care was nominated by our stakeholders as a priority question for future research. The 2008 AHRQ review did not specifically address cost-effectiveness as a key question but reported on its implications in relation to the business case for integration (see research question #9). The Department of Veterans Affairs, used as a case study in the AHRQ report, found collaborative care interventions to be cost-effective based on a meta-analysis of over ten cost-effectiveness analyses. The AHRQ report however, did not look at this question across populations or settings and suggested that questions remain unanswered regarding whether targeting high-risk cases (based on medical comorbidities and/or the presence of medical complexity) produces greater cost-effectiveness.

There is good reason to consider cost-effectiveness from a variety of perspectives including payer and patient. In addition, a societal perspective estimates all gains and losses, reflecting the effectiveness and potential harms of an intervention as well as its direct and indirect costs.

## Research Need # 9 Studies examining the business case for integration. When a practice or system invests in integrated care staffing and services, what are the revenues generated, and what are the effects on downstream costs such as hospitalization? Studies could take the perspective of the practice, the health care system, or the payer

Rationale. The “business case” for integration focuses on the operational costs of the integrated care at the practice or the health care organization level. The business case analysis is financial and does not examine patient health status, functioning, or employment status. Such patient-centered outcomes are considered in cost-effectiveness analyses.

Many of these business case issues are highly dependent on local practices and financial arrangements. For example, if a practice implements integrated care and reduces ER and hospital costs, but receives little or no increase in fee-for-service or bundled compensation for this effort, the practice will have no “business case” if it is the business entity at risk. The business case for the practice will be dependent on the amount of fee-for-service or case-based reimbursement for the mental health services provided, minus the cost to the practice of providing those services. A practice might not receive any savings from the avoided ED visit, specialty visits, and hospitalizations. A somewhat different perspective would be to conduct a business case analysis for the overall care organization: primary care practice, hospital, and specialists considered as a single entity. These analyses could be conducted in coordination with study question #4 on sustainability of integrated care. The focus in that question is on organizational factors, but examination of financial “business case” factors could be conducted at the same time and in the same practices.

## Research Need #10 Effectiveness of measurement-based integrated care for case identification, treatment, and monitoring, focusing on mental health conditions other than depression

Rationale. A significant aid to integrated care in depression has been the availability of brief instruments (e.g., Patient Health Questionnaire) to screen for depression and assess progress over time. Short instruments which can be administered by nonspecialist personnel are critical given the time- and resource-constrained environment of primary care practice. The stakeholder panel emphasized the importance of integrated care models that treated the multiple mental health problems seen in primary care practices; a different system for each diagnosis was felt to be impractical for most primary care settings. The use of short diagnostic and assessment instruments may seem intuitive, but each instrument must be validated as well as assessed for its usability in daily practice.

## Research Need #11 Effectiveness of integrated care for patients with dual Medicaid and Medicare eligibility

Rationale. The 2008 AHRQ review asked to what extent the impact of integrated care programs on outcomes varies for different populations.2 They found that most work had been done with older patients and found some positive results with minority populations. The review concluded that existing literature remains unclear as to who is most likely to benefit from integrated care. Our stakeholders highlighted patients with dual Medicaid and Medicare eligibility (dual eligibles) as a population for whom research is needed to determine whether integrated care is effective.

The nine million dual eligibles nationwide are a vulnerable and costly group. They tend to be poor and report lower health status than other beneficiaries, and cost Medicare about 60% more than nondual eligibles.20 Among dual eligibles, approximately 60% of the disabled and 20% of the elderly have mental disorders.21 In addition, dual eligibles are three times more likely to be disabled and have higher rates of diabetes, pulmonary disease, stroke, and Alzheimer’s disease.

## Research Need #12 Effectiveness of integrated care in the presence of both general medical comorbidities such as diabetes or chronic pain, as well as mental health comorbidities, such as depression and anxiety

Rationale. This question was addressed in the 2008 AHRQ review under their key question 2: To what extent does the impact of integrated care programs on outcomes vary for different populations?2 The review found that only depression research had examined the possibility of improved medical condition outcomes as a result of integrated care and proposed randomized controlled trials, demonstrations, and qualitative studies to examine which groups of patients are most likely to benefit from integrated care. Our stakeholders highlighted the population of mental health patients with comorbid general medical conditions as a population of particular interest in primary care. A recent AHRQ topic development project explored this question as part of a larger treatment review for patients with comorbid general medical and mental health diagnoses and has been put forward by AHRQ for topic refinement. Given the upcoming AHRQ review, future research should perhaps focus on other, less common, mental health conditions also seen in primary care. Patients with serious mental illness such as schizophrenia and bipolar disorders may present first in primary care. This population typically has comorbid general medical conditions. There is currently very little research on the effectiveness of integrated care for these individuals.

## Research Need #13 Effectiveness of the medical home as a model/strategy for integrated care. The “medical home” could be a primary care office for many patients, but could also be a specialty mental health practice with elements of primary care integrated to form the “medical home.”

Rationale. This research need was nominated by our stakeholders and is also present in the 2008 AHRQ review.2 The AHRQ review found that most models integrate mental health into primary care; fewer do the opposite. Our literature scan in the first months of the project also found few studies published since 2008 on the topic of integrated care in specialty mental health practices. A number of states have adopted the concept of the medical home and Medicare has proposed demonstration projects to test the effectiveness of the medical home concept. Under the terms of a Medicare demonstration project, volunteer practices would receive a special payment to serve as a medical home.

A number of definitional issues need to be considered in relation to the idea of the medical home, particularly in terms of the overlap with integrated care, co-location, collaboration, care management, and patient-centered care.

“Medical home” (often called the “patient-centered medical home,” or PCMH) as a model for integrated care is in the early stages of definition and implementation. First steps could involve an environmental scan to identify (a) the key elements of “medical home” as a strategy for integrated care, (b) primary care where “medical home” has been implemented through integration of mental health care into primary care, and (c) mental health specialty practices where “medical home” has been implemented through integration of primary care into mental health specialty practice and sustained as a model for integrated care. Additionally, an examination of the evidence on “medical home” as a strategy for integrated care would identify answers to questions such as (1) who is most likely to use this type of care, (2) who is most likely to benefit from this type of care, (3) should “medical home” as a strategy be directed at all persons with identified mental illness (or are certain mental illness diagnoses like depression more effectively addressed in this manner compared to other diagnoses such as schizophrenia or bipolar disorder), (4) how does “medical home” as a strategy for integrated care vary by patient severity, (5) how does “medical home” as a strategy for integrated care vary by setting, and (6) what is the evidence for feasibility of integrated care models and medical home models in rural areas, where there is lack of or limited availability of mental health and primary care professionals? We recognize that the answers to many of these targeted questions above may not be known, but they would further inform the refinement of the PICOTS.