# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CQI: continuous quality improvement
CTSA: Clinical and Translational Science Awards
EPC: Evidence-based Practice Center
ES: effect size
FQHC: federally qualified health center
FRN: future research need
HAM-D: Hamilton Rating Scale for Depression
HRSA: Health Resources and Services Administration
HSR PROJ: Health Services Research Projects in Progress
ICC: intraclass correlation
IMPACT: Improving Mood Promoting Access to Collaborative Care Treatment
IT: information technology
NCI: National Cancer Institute
NCQA: National Committee for Quality Assurance
NIAAA: National Institute on Alcohol Abuse and Alcoholism
NIAMS: National Institute of Arthritis and Musculoskeletal and Skin Diseases
NIDA: National Institute on Drug Abuse
NIH: National Institutes of Health
NIMH: National Institute of Mental Health
NQF: National Quality Forum
OR: odds ratio
PCMH: patient-centered medical home
PICOTS: population, intervention, comparator, outcome, timeframe, setting
PTSD: posttraumatic stress disorder
QALY: quality-adjusted life year
QIDS-SR-16: Quick Inventory of Depressive Symptomatology - Self Report
RePORTER: Research Portfolio Online Reporting Tools—Expenditures and Results
RESPECT-D: Re-Engineering Systems for Primary Care Treatment of Depression
RFA: request for application
SAMHDA: Substance Abuse and Mental Health Data Archive
STAR*D: Sequenced Treatment Alternatives to Relieve Depression
UNC: University of North Carolina
VA: U.S. Department of Veterans Affairs