# Results

## Research Needs

Appendix E provides a synthesis of research needs from the CER, those proposed by Panel members during the individual introductory calls, and results of the literature search update. A total of 10 research needs were identified through a combination of the CER findings and conversations with the Stakeholder Panel. These research needs were grouped by specific populations addressed in the CER. The Stakeholder Panel was asked to review this preliminary list of research needs during the first teleconference call. As stated in the Methods section, the Stakeholder Panel then ranked the research needs. The results of the first survey ranking the importance of these research needs are found in Appendix F. The response rate was 100 percent (n=9); 8 (of 10) research needs received votes. The EPC generated the final ranking of research needs taking all Stakeholder Panel comments into account.

The Stakeholder Panel discussed the implications of the published studies and ongoing trials found in the literature search update. The Panel members proposed condensing research needs that addressed similar issues, and they identified three priority patient groups (critically ill/ICU patients, patients presenting to the emergency department [ED], and immunocompromised patients). Furthermore, they noted that while large European trials have been conducted in some patient populations, they have not been studied in the U.S. context where differences in medical culture, regulation and practice exist. This has limited adoption of procalcitonin, for example, in patients who present to ambulatory care/ED settings in the U.S. with suspected lower respiratory tract infections. Finally, the Panel proposed addressing both adult and pediatric populations in each research need rather than treating pediatrics as a separate research need. The final three research needs are stated in Table 2.

Table 2 Prioritized list of research needs

1. | The use of procalcitonin in the management of critically ill patients (all ages) with suspected lower respiratory tract infection (LRTI) or general infection.
2. | The use of procalcitonin in the management of patients (all ages) with suspected LRTI in the ambulatory care/emergency department setting in the U.S.
3. | The use of procalcitonin in the management of the immunocompromised patient (all ages).

## Research Questions

A list of preliminary research questions drafted by the EPC across each of the prioritized research needs was submitted for feedback to Panel members via email following the second Stakeholder Panel call. Following this feedback, the second survey of research questions was submitted to Panel members for ranking prior to the third Stakeholder Panel call. The results of the second survey ranking the importance of research questions are found in Appendix G.

As with the research needs, the research questions were presented in a random order for the survey. The response rate was 100 percent (n=9); all questions received votes. There was discussion on the appropriate threshold with respect to a short list of research questions including further condensing the questions. For example, similarities were noted on the three questions related to ICU patients and Panel members were of the opinion that these could be addressed in the same request for application/grant submitted for consideration for future research. The Stakeholder Panel also discussed the importance and usefulness of future studies on the top-ranked questions based on the voting results at the third Panel call. Future research issues brought forth for discussion at this call included:

- Addressing procalcitonin guidance in pediatrics: The “cut points” are likely to vary between adult and pediatric populations; studies that include all age groups should stratify results by age to assess the contribution of procalcitonin in pediatrics independently from adults, as well as sub-groups within pediatric populations. However, rather than formulating specific research questions for pediatrics, it would be beneficial to integrate this segment of the population within the three patient groups prioritized in the research needs (i.e., ICU, outpatient ED, immunocompromised), recognizing that future procalcitonin studies in children will need a separate analysis. For example, in pediatrics, the duration of treatment in someone with suspected sepsis and negative culture is often arbitrary.
- Future studies in immunocompromised patients should address not only those with neutropenia, but also other subgroups that were specifically excluded from the studies reviewed in the CER; these subgroups include solid organ and stem-cell transplant recipients, patients with advanced HIV infection, and patients on potent immunosuppressive therapy.
- Future studies should address both the duration of use of procalcitonin and initiation of antibiotic therapy based on procalcitonin results in various populations (e.g., stopping initiation could be addressed in an urgent care/ED setting and reducing duration in the ICU setting).

These discussions formed the basis for the final prioritized list of six research questions (Table 3, in order of priority).

Table 3 Prioritized list of research questions

1. | For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a PCT-guided strategy used to determine the duration of antimicrobial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?
2. | For the otherwise healthy adult or pediatric patient who presents to ambulatory care/ED with fever and/or suspected acute LRTI, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?
3. | For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?
4. | For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a subsequent decrease in the serial PCT measurement indicate effective empiric treatment of the bacterial infection?
5. | For the immunocompromised patient who presents with suspected LRTI/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?
6. | For the immunocompromised patient with suspected LRTI/sepsis, does a PCT-guided strategy used to determine the duration of antibacterial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?

ED = emergency department; ICU = intensive care unit; LRTI = lower respiratory tract infection; PCT = procalcitonin

The Stakeholder Panel also discussed potential study designs for the prioritized list of research questions at the third Panel call. Issues brought forth for discussion on this call included:

- One study design has the potential to address multiple research questions, e.g. questions addressing the use of procalcitonin to determine whether to start antibiotics, and other questions addressing whether to do sequential procalcitonin testing each day.
- What is/are the objective(s) of the study? This is a critical step to determine a priori, as separate research questions would be required to address what procalcitonin actually measures in certain populations, how it correlates with other diagnostic markers, and how it affects practice or health outcomes.
- What is the appropriate gold standard? Several clinical studies have compared procalcitonin to an imprecise investigator-adjudicated gold standard comprised of culture and clinical examination data to determine presence or absence of bacterial infection. Microbial etiology using modern molecular diagnostics would be an appropriate gold standard and essential to correlating procalcitonin results with infection etiology.
- What outcomes should be considered for evaluations of treatment strategies using procalcitonin? These should include fewer antibiotic adverse events and emergence of drug-resistant pathogens.
- What factors may influence trial outcomes of treatment strategies using procalcitonin? When considering study design options, there is a need to balance issues of equivalence with the practicality of carrying out a randomized controlled trial (RCT) or cluster RCT. For example, noninferiority trials are increasingly used to identify a new treatment strategy that may have approximately the same efficacy as an existing treatment strategy but may offer other benefits such as fewer side effects and reduced drug resistance. With noninferiority trials, the choice of noninferiority margin should be statistically based, clinically relevant, and appropriately conservative to reflect the uncertainties in the evidence. However, the magnitude of the noninferiority margin is inversely proportional to sample size, which could affect the feasibility of carrying out a RCT or cluster RCT.

The final prioritized list of research needs and research questions with PICOTS information are stated in Table 4.

Table 4 Prioritized list of research needs and research questions with PICOTS information

Research Need | Research Question | Population(s) | Interventions | Comparators | Outcomes | Timing | Settings
The use of procalcitonin in the management of critically ill patients (all ages) with suspected LRTI or general infection Reason(s) for Research Need: For adults, insufficient evidence on health outcomes (e.g. antibiotic adverse events); Results from available studies are inconsistent (e.g. how adverse effects are defined, lack of details on types of adverse reactions) For pediatrics, insufficient or imprecise information given the limited number of studies | [underlined: 1.1] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a PCT-guided strategy used to determine the duration of antimicrobial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? [underlined: 1.2] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a subsequent decrease in the serial PCT measurement indicate effective empiric treatment of the bacterial infection? [underlined: 1.3] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? | Critically ill adult or pediatric patient with suspected or proven pneumonia/sepsis | Clinical criteria with cultures if available plus PCT thresholds for determining presence/absence of bacterial infection | - Clinical criteria with cultures if available; - Institutional strategies for reducing antibiotic use (e.g. ASP, educational programs targeting staff in the outpatient setting) | - Hospital or ICU admission rate; - Hospital/ICU LOS; - Severity of illness; - ABT-associated adverse reactions (e.g. allergic reactions); - Emergence of drug resistant pathogens or superinfection; - Mortality (e.g. 30-day, hospital); - Antibiotic use (e.g. duration, days without ABT and total ABT exposure in children) | On admission or suspicion of infection, duration of follow up (e.g. ≥ 30 days) | Hospital ICU
The use of procalcitonin in the management of patients (all ages) with suspected LRTI in the ambulatory care/emergency department setting in the U.S. Reason(s) for Research Need: For all ages, not the right information as results may not be applicable to U.S. setting; For pediatrics, insufficient or imprecise information given the lack of studies | [underlined: 2.1] For the otherwise healthy adult or pediatric patient who presents to ambulatory care/ED with fever and/or suspected acute LRTI, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? | Adult or pediatric patient with no underlying medical conditions who presents with fever/suspected acute LRTI including community- acquired pneumonia, exacerbation of chronic obstructive pulmonary disease, and bronchitis | Clinical criteria with cultures if available plus PCT thresholds for determining presence/absence of bacterial infection | - Clinical criteria; - Strategies to reduce antibiotic use (e.g. CPGs, education) | - Hospital/ICU admission rate; - Hospital/ICU LOS; - Severity of illness; - ABT-associated adverse reactions (e.g. allergic reactions); - Emergence of drug resistant pathogens or superinfection; - Mortality (e.g. 30-day, hospital); - Days of restricted activity with PCT-guided therapy; - Relapse of infection; - Antibiotic use (e.g. duration, days without ABT and total ABT exposure in children) | On admission, duration of follow up (e.g. ≥ 30 days) | - Ambulatory care; - Primary care clinic; - ED
The use of procalcitonin in the management of the immunocompromised patient (all ages) Reason(s) for Research Need: Insufficient or imprecise information given the limited number of studies; Patients with certain conditions were excluded from these studies, including neutropenia, transplant recipients (stem-cell or solid organ), and other patients on immunosuppressive therapy | [underlined: 3.1] For the immunocompromised patient who presents with suspected LRTI/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? [underlined: 3.2] For the immunocompromised patient with suspected LRTI/sepsis, does a PCT-guided strategy used to determine the duration of antibacterial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? | Immunocompromised patients including patients infected with human immunodeficiency virus and with a CD4 count of < 200 cells/mm3, neutropenic patients, transplant recipients (stem-cell or solid organ), and other patients on immunosuppressive therapy | Clinical criteria with cultures if available plus PCT thresholds for determining presence/absence of bacterial infection | - Clinical criteria with cultures if available; - Institutional strategies for reducing antibiotic use (e.g. ASP, educational programs targeting staff the outpatient setting) | - Hospital or ICU admission rate; - Hospital/ICU LOS; - Severity of illness; - ABT-associated adverse reactions; - Emergence of drug resistant pathogens or superinfection; - Mortality (e.g. 30-day, hospital); - Days of restricted activity with PCT-guided therapy; - Relapse of infection; - Antibiotic use (e.g. duration, days without ABT and total ABT exposure in children) | On admission or suspicion of infection, duration of follow up (e.g. ≥ 30 days) | - Outpatient/ED; - Hospital ward; - ICU

ABT = antibiotic therapy; ASP = antibiotic stewardship program; CPG = clinical practice guideline; ED = emergency department; ICU = intensive care unit; LOS = length of stay; LRTI = lower respiratory tract infection; PCT = procalcitonin

## Study Design Considerations

The focus of the prioritized list of research questions is on the contribution of procalcitonin-guided clinical algorithms aimed at empirically treating suspected or confirmed bacterial infection in non-outbreak settings, including primary care, emergency/ambulatory care and intensive care. To that end, similar study designs may be used to address questions of the contribution of procalcitonin to the decision to initiate, maintain or discontinue antimicrobial therapy across a range of populations; in fact, a single study may sufficiently address all questions within a research need. Table 5 presents suggestions for the most valid and feasible study designs for future research of procalcitonin that could be considered for each of the prioritized research needs. The CER did not compare outcomes of using procalcitonin guidance versus antibiotic stewardship programs, nor did it address whether addition of procalcitonin to an antibiotic stewardship program improves outcomes. Therefore, a systematic review may be warranted to identify research needs from studies comparing procalcitonin-based strategies to institutional programs aimed at reducing antibiotic use before undertaking new primary research.

Table 5 Study design considerations

Study Design Considerations | Randomized Controlled Trial | Controlled Before-After Study | Modeling
Description of design | Individuals randomly assigned to receive PCT-guided treatment strategy or standard care. Patients are followed during implementation for antibiotic use and health outcomes. Longer followup post implementation may be required if sustainability of outcome is desired (e.g., reduction of antibiotic use). Cluster RCTs that randomize at a hospital or ward level may be more suitable for population-level strategies when outcomes for individuals from a given unit are not independent. If pooling data across institutions is required, consensus on PCT cut-off points, standard care, outcome measures, minimum datasets and followup periods would be needed. | Antibiotic use and other health outcomes are compared in two or more groups of patients at the beginning and end of the study period. The study group receives the PCT-guided antibiotic treatment strategy part way into the study, and the control group receives standard care without use of PCT. Changes in outcomes from the beginning to the end of the study are compared across groups. Investigator controls timing of measurement(s) and variables measured, but not all intervention variables are in the control of the investigator. If pooling data across institutions is required, consensus on standards of care, outcome measures, minimum datasets and followup periods would be needed. | Simulation model developed and validated to assess the value of individual strategies or individual components of comprehensive strategies across a range of populations, settings and conditions. Simulation models assume statistical association (e.g. between reduced antibiotic use and antibiotic-associated adverse events) and predict the consequences of the assumption (incidence of drug resistant pathogens). Agent based modeling (i.e., agent is the infectious bacteria) can be used to simulate the process of infectious disease transmission and be used to track drug resistance. This would allow for assessing the impact of a PCT-guided treatment strategy for reducing antibiotic use on rates of drug resistance over time.
Advantages of study design for producing a valid result | Best method to control for selection bias but potentially at the cost of generalizability. It should produce the most internally valid results. | Simple, efficient design with generalizable results. Design offers the ability to assess the temporal relationship between outcomes and ‘nonrandomizable’ events, e.g., if a hospital or unit has already adopted the use of PCT. Highly susceptible to confounding variables such as other concomitant antimicrobial therapy or dual viral/bacterial infection, regression to the mean and maturation effects. Internal validity may be strengthened by collecting data on confounding variables and matching study and control groups on pre-intervention outcomes of interest (e.g. antibiotic use, infection rates). Adding multiple pre-intervention observations is particularly important for evaluating temporal trends. Adequate statistical methods will be needed to control for confounders and secular trends in resistance and infection rates. | May be the best option to use when questions cannot be addressed using conventional clinical trial methods or existing data analysis, e.g. assessing the impact of various antibiotic treatment strategies on rates of drug resistance over the long term. May inform and help focus future clinical trials and data collection. Models can be tailored to multiple end users and perspectives, conditions and settings to enhance generalizability of findings and to help target interventions (different populations may call for different algorithms). Other forms of modeling (e.g. compartment based, decision tree, etc.) can be informative but will require more assumptions and thus greater variability with less confidence in the results. Its usefulness will be limited by available data and assumptions.
Resource use, size and duration | Depending on the strategy and desired effect size and outcome (e.g. the acceptability margins used to claim equivalence or noninferiority), costs, sample size and staff time needed for recruitment and implementation could be high. Recruitment of unit “clusters” willing to be randomized may constrain sample size. Duration likely to be a few weeks, which may keep costs down, but longer followup (several years) may be required to account for the lag between change in antibiotic use and rates of nosocomial drug resistance/super-infections. | Generally less resource intensive than an experimental design, but sample size will depend on desired effect and magnitude. Otherwise, size and duration issues would be similar to RCT. | May require substantial personnel time but is generally less resource intensive than primary studies. May require primary data collection to inform components of the model if reliable estimates cannot be obtained from the literature, empiric studies or experts.
Ethical, legal, and social issues | Perception of not receiving efficacious care can pose an ethical issue and barrier to recruitment if standards of clinical equipoise are not met. For cluster RCTs, a waiver of informed consent would be required. Legal mandates or clinical culture may impede randomization to new interventions or supersede trial objectives. | Perception of not receiving efficacious care can pose an ethical issue and barrier to recruitment if standards of clinical equipoise are not met. | Additional data collection may require institutional approvals or informed consent.
Availability of data or ability to recruit | Given the high mortality rates for sepsis, patient or their families may be reluctant to enroll in an RCT. Cluster RCTs require collaborative network of sites willing to participate. | Recruiting is feasible. Design may offer the best way to study interventions where randomization may be unacceptable to patients or providers. | Data would be obtained primarily from published sources, proprietary institutional databases, and expert opinion.

PCT = procalcitonin; RCT = randomized controlled trial

Requirements of study design include defining setting specific cut-off ranges and functional assay sensitivities for procalcitonin, validated prospectively with other approaches aimed at reducing antibiotic use, to address the optimal strategy for safely addressing antibiotic overuse and emerging multidrug resistance. Study populations at institutions or individual practices that do not offer procalcitonin testing may serve as useful controls if baseline characteristics can be balanced. Investigators will need to weigh the study requirements for adequate power, desired outcomes and feasibility.14

Since cut-ranges are likely to vary between adult and pediatric populations, studies that include all age groups should stratify results by age to assess the contribution of procalcitonin in pediatrics independently from adults, as well as patient groups within pediatric populations. Studies should account for situations where the physician may decide to override the procalcitonin-guided clinical algorithm, e.g., when the procalcitonin value is low but the absolute risk of bacterial infection in a patient is high. To that end, stratification may be needed to assess the contribution of procalcitonin in populations where the uncertainty or absolute risk of bacterial infection may vary. Stratification according to drug class may be needed to account for sustained declines in antibiotic use across drug classes and antibiotic resistant isolates.

New institutional practices aimed at reducing unnecessary antibiotic use may be introduced during the course of the study as a result of new policy decisions, e.g., legislative mandates. To that end, quasi-experimental designs may offer the best approaches to account for factors that may be outside the control of the investigator. Information on barriers to implementation of procalcitonin-guided strategies and durability of results should be obtained. While a comparison of changes in antibiotic use across study arms can be accomplished in the short term, durability of the results and declines in the rates of resistance may not be observed for several years and would require longer followup. The ability to assess temporal trends in resistance and infection rates will be important in interpreting longer-term outcomes to which simulation modeling may be valuable.