# Methods

## Identification of Research Needs

Figure 2 outlines the process steps of this Future Research Needs project. The details are described in the text. First, an initial set of evidence gaps was identified through the BCBCA TEC EPC CER. The literature search was updated and clinicaltrials.gov was searched to identify any ongoing or newly completed research studies that might address the research needs. Next, a group of nine stakeholders (Stakeholder Panel) representing diverse perspectives was formed. Through an iterative process the stakeholders prioritized and refined the research needs and research questions (see section on engagement of stakeholders, researchers and funders) using the SurveyMonkey™ Web site. Finally, the exploration of various research designs was conducted by the (Evidence-based Practice Center) EPC. Details of these steps follow.

Figure 2 Process flow diagram

AHRQ = Agency for Healthcare Research and Quality; CER = Comparative Effectiveness Review; EHC = Effective Health Care; EPC = Evidence-based Practice Center; SP = Stakeholder Panel

Figure 2 outlines the 11-step process steps of this future research needs project. First, research needs were identified through the BCBSA TEC EPC CER. The literature search was updated and clinicaltrials.gov was searched to identify any ongoing research studies that might address the research needs. Next, stakeholders were identified and through and iterative process the research needs were shared with and refined by these stakeholders. A group of nine stakeholders (Stakeholder Panel (SP)) representing diverse perspectives was formed; this group prioritized the refined research needs, and generated research questions. research needs were prioritized through the Web using the SurveyMonkey® Web site. Finally, the exploration of various research designs was conducted by the EPC. The details are described in the text.

## Literature Search Update

To identify recently published and ongoing studies, we conducted an updated search on April 22, 2012 using MEDLINE^®^ (via PubMed^®^), Embase.com, The Cochrane Library, and the ClinicalTrials.gov databases (see Appendix B). The update captured 96 citations published since March 20, 2012. Searches gathered 88 comparative studies, randomized and nonrandomized, as well as eight clinical trials currently under way. The purpose was to identify important studies addressing research needs that ought to be taken into account when developing potential research questions, rather than to fully update the CER. Given the recent search time period as well as the fact that MEDLINE^®^ and Embase.com contain many “in process” citations with only titles and/or abstracts, searches relied heavily on a “free text” search approach to retrieve the most current procalcitonin citations. Citations were then individually reviewed for inclusion by study type and relevance.

## Criteria for Prioritization

To establish criteria for prioritizing research needs and research questions, we modified the Effective Health Care (EHC) Program Selection Criteria to be applicable to primary research rather than to systematic reviews of original research.10 These criteria are presented in Table 1. The modified EHC Program Selection Criteria were distributed to Panel members each time they were asked to prioritize research needs or research questions. Study design considerations was handled by the EPC in accordance with the recent Future Research Needs methods report by the Research Triangle Institute International-University of North Carolina at Chapel Hill (RTI-UNC) EPC on behalf of the Agency for Healthcare Research and Quality (AHRQ).11 The Stakeholder Panel provided insight into how future research agendas and proposed studies to address research needs fit within these prespecified criteria.

Table 1 Prioritization criteria for research needs and proposed research studies

Category | Criteria
Current importance | - Incorporates both clinical benefits and harms; - Represents important variation in clinical care due to controversy/uncertainty regarding appropriate care; - Addresses high costs to consumers, patients, health-care systems, or payers; - Utility of available evidence limited by changes in practice, for example disease detection
Potential for significant health impact | - Potential for significant health impact:; ○ To improve [underlined: health outcomes]; ○ To reduce [underlined: significant variation] related to quality of care; ○ To reduce [underlined: unnecessary burden] on those with health-care problems; - Potential for significant economic impact, reducing unnecessary or excessive costs; - Potential for evidence-based change; - Potential risk from inaction, for example lack of evidence for decision-making produces unintended harms; - Addresses inequities, vulnerable populations, patient subgroups with differential impact (e.g., by age)
Incremental value | - Adds useful new information to existing portfolio of research on topic, or; - Validates existing research when body of evidence is scant
Feasibility | Factors to be considered:; - Interest among researchers; - Duration; - Cost; - Methodological complexity (e.g., do existing methods need to be refined?); - Implementation difficulty; - Facilitating factors; - Potential funders

## Methods for Ranking Research Needs

Research needs were ranked via the SurveyMonkey™ Web site. The Stakeholder Panel was sent a link to the Web site where they ranked the research needs from 1 to 5 and generated research questions for each need. The survey allowed each rank to be used only once. Points were assigned to each need: 1 point for a ranking of fifth, up to 5 points for a ranking of first. The research need with the largest number of points was assigned the highest priority. The research needs were presented in a random order for the survey.

For each research need multiple research questions may be needed that encompass the basic science of how procalcitonin fits into the innate response, as well as the properties and use of procalcitonin in diagnosis, prognosis, and treatment planning. Discussions held during the introductory calls and the first teleconference with the Stakeholder Panel revealed considerable uncertainty about the reliability of procalcitonin measured with newer testing platforms and about the predictive values and outcomes associated with its use in lesser studied populations such as pediatrics.

The properties of a diagnostic test (e.g. sensitivity, specificity, predictive values) may vary across testing platforms and populations; they may be well-defined in some populations and not in others. Gauging the progression of knowledge of a test's diagnostic properties across patient populations may help refine the research in need of further study. To that end, a conceptual framework for evaluating diagnostic tests was used to assist in discussions of the research needs during the second teleconference with the Stakeholder Panel.12 This framework recognizes that a new test goes through several stages of evaluation before its usefulness in clinical practice is established. It extends from basic testing principles (Level 1) through clinical applications in diagnosis (Levels 2 and 3) and treatment decisions (Level 4) to patient and societal outcomes (Levels 5 and 6). The study designs and expectations are different for earlier levels than for later levels used in specific clinical problems. If sufficient evidence for earlier levels exists, then higher-level questions could be pursued. However, insufficient evidence at lower levels should be addressed before taking on higher-level studies. The framework is presented in Figure 3.

Figure 3 Framework of potential uses for procalcitonin

QALY = quality-adjusted life year; ROC = receiver operating characteristics

This framework recognizes that a new test goes through several stages before becoming generally accepted and used by health care professionals in daily practice. It extends from basic testing principles (Level 1) through clinical applications in diagnosis (Levels 2 and 3) and treatment decisions (Level 4) to patient and societal outcomes (Levels 5 and 6). The study designs and expectations are different for earlier levels than for later levels used in specific clinical problems. If sufficient evidence for earlier levels exists, then higher level questions could be pursued. However, insufficient evidence at lower levels should be addressed before taking on higher level studies.

The comments received from the Stakeholder Panel during the calls and as part of the survey were reviewed by EPC staff and incorporated where necessary. In addition to the modified EHC Program Selection Criteria, special attention was paid to research needs that overlapped with existing research. The reasons for each research need were categorized based on a classification scheme created by the Johns Hopkins University EPC on behalf of AHRQ.13

## Engagement of Stakeholders, Researchers, Funders

Central to the methodology of this report was the use of the Stakeholder Panel to identify and prioritize research needs. A single multidisciplinary Stakeholder Panel was convened to provide input on this project. The Panel included individuals interested in comparative effectiveness research and knowledgeable about current research on sepsis and biomarkers. They consisted of nine participants representing diverse perspectives (from infectious diseases, critical care, internal medicine, health policy), methodological expertise (e.g., guidelines development, clinical trials, epidemiology), and consumer and payer representation. Panel members provided specific clinical and research experience on procalcitonin guidance, including intensive care, respiratory tract infections, pediatric care, antimicrobial use, and other diseases and novel interventions.

The Stakeholder Panel was asked to recommend important studies published since the BCBSA TEC EPC completed the CER, revise and prioritize the research needs listed in the CER and gathered throughout this project, and develop and prioritize a list of potential research questions to address those research needs. As required by AHRQ, conflict of interest forms were completed by all Panel members and staff on this project. The Stakeholder Panel was asked to participate in three conference calls (1 hour each) over the project duration, and some interim communications by email. In addition, a brief introductory call (30 minutes) was scheduled separately with each individual member, to provide an overview of the project, to discuss the role of the Stakeholder Panel, and to solicit preliminary suggestions on further research needs. The first call was held on April 23, 2012. During this call, the members were asked to review the preliminary list of research needs. This list was a synthesis of evidence gaps from the CER, those proposed by Panel members during the individual introductory calls, and results of the literature search update. Members reviewed a list of revised following this call. The Stakeholder Panel was then asked to rank, via an online survey, their top 5 research needs from 1 to 5 with 1 having the highest priority and 5 the lowest. Panel members rated these research needs based on revised EHC program selection criteria (Appendix C).

The second call was scheduled on May 8, 2012. During the second call, Stakeholder Panel members were invited to review the prioritized list of research needs and “brainstorm” research questions to address each research need. Members reviewed a list of potential research questions following this call. The Stakeholder Panel was then asked to prioritize the research questions via an online survey instrument (using SurveyMonkey™) similar to that used for selection of research needs. As with the online survey for research needs, members were asked to rank their top 5 research questions from 1 to 5 with 1 having the highest priority and 5 the lowest (Appendix D). The project team collated the “votes” and reported the results at the third call, convened on June 4, 2012, for prioritization of research questions. The meeting participants reviewed the results and further discussed the importance of the research questions to patient and clinical decision making. These discussions formed the basis for the final prioritized list of research questions submitted to AHRQ in this report. All teleconference call materials were distributed a few days prior to scheduled calls.

## Research Question Development and Study Design Considerations

Key research questions for each research need were generated through an online survey instrument and discussions by the Stakeholder Panel (discussed previously). The project team compiled a final list of research questions taking the feedback of the Panel into consideration. The research questions were characterized using the PICOTS framework using the population(s) (P), interventions (I), comparators (C), outcomes (O), timing (T), and settings (S). This approach is consistent with the guidance produced by the Johns Hopkins University EPC on behalf of AHRQ.13 The project team later evaluated potential study designs to address each of the key research questions. The appropriateness of any one study design to address a research need was further evaluated using the following criteria:

- Advantages of the study design for producing a valid result
- Resource use, size, and duration
- Ethical, legal, and social issues
- Availability of data or ability to recruit

The project team used the guidance produced by the RTI-UNC EPC on behalf of AHRQ as a guide during discussions of the least biased study design that was likely to be feasible to undertake.11 To enhance public engagement, AHRQ will solicit broader input on this document by making it available for public input, which will be incorporated and reflected in the final report.